# Conclusions

We searched the literature, conducted an audit of EPC evidence reports, and sought information from other organizations that are involved with evidence synthesis. Despite these efforts, we identified little detail or consistency in the frameworks used to determine research gaps within systematic reviews. In general, there is no widespread use or endorsement of a specific formal process or framework for identifying research gaps using systematic reviews.

We developed a framework to facilitate the systematic identification of research gaps through the classification of where the current evidence falls short and why the evidence falls short. A worksheet was developed to facilitate the use of the framework when completing a systematic review and thus facilitate the use of a systematic process to identify research gaps.