# Background

During the completion of a systematic review, investigators routinely identify gaps in the available evidence. Evidence reports produced by evidence-based practice centers (EPCs) have always included a future research section. However, in contrast to the explicit and transparent steps taken in the completion of a systematic review, there has not been a systematic process for the development of the future research sections.

With a goal of ultimately developing guidance for the EPC program, AHRQ asked EPCs to respond to seven questions about the development, prioritization, and presentation of research needs (see Appendix A). The JHU EPC was assigned question 1, which is the following question:

Define frameworks for determining research gaps conducted within a systematic review.

a i. What are the various frameworks (concepts and organizing principles) used to determine the research gaps within a systematic review?
  ii. How often do the identified gaps extend beyond the reach of the original key questions?
b Is there any evidence that one method for identifying research gaps is more valid than another?
c Is there any evidence that one format for presenting research gaps is more useful than another?

We defined a research gap as a topic or area for which missing or inadequate information limits the ability of reviewers to reach a conclusion for a given question. A research need was defined as a gap that limits the ability of healthcare decision makers (patients, physicians, policy makers, etc.) from making decisions. A research gap may not be a research need if filling the gap would not be of use to stakeholders that make decisions in healthcare. Our project focused on research gaps, but we broadened our methods to include “research needs” since this distinction is not always made. While prioritization of research needs and assessment of feasibility of various study designs may have been considered in processes by other organizations as noted later in the report, these were not within the scope of the above questions.

## Objective

Our objective was to identify and pilot test a framework for the identification of research gaps.