# Appendix F Step 4: Development of Framework—Instructions for Research Gaps Abstraction Worksheet

A research gap is a topic or area for which missing or inadequate information limits the ability of reviewers to reach a conclusion on a given question. This worksheet is designed to facilitate the identification and organization of research gaps during evidence reviews sponsored by AHRQ. Our aim was to design a simple, user-friendly worksheet to help investigators record research gaps. We envision that investigators would fill out this worksheet soon after the data synthesis phase, while in the process of writing the results section of the evidence report.

To facilitate the aggregation of research gaps identified by different people, each person should put his/her name/initials and date of completion on the top right corner of the sheet. Each person should also write the worksheet page number and the key question number on the top right corner of the sheet. We encourage members to be consistent in how they choose to fill out this worksheet, both within themselves as well as with other members of the investigative team.

In the worksheet table, each row is one research gap and is numbered accordingly (“Serial Number”).

## Reason(s) for Gaps

This column allows members to indicate why the research gap exists. The classification of the reasons for gaps are listed and coded in the legend of the gaps abstraction worksheet. Members should choose the most important reason(s) for the existence of the research gap. That reason selected should be the reason(s) that most precludes conclusions from being made. Put another way, members should consider what would be needed to allow for conclusions to be made. Members may choose to enter codes for more than one reason in this column, as appropriate. The specific reasons for gaps are listed in the footnote of the table and described below:

- Insufficient or imprecise information. Insufficient information in identified studies can arise if no studies are identified, if a limited number of studies are identified, or if the sample sizes in the available studies are too small to allow conclusions. If the information available in identified studies is insufficient to allow a conclusion or if the estimate of the effect (usually achieved from a meta-analysis) is imprecise there is a research gap. Correspondence to grading systems:
  ○ EPC SOE: Precision is a required domain.
  ○ GRADE: The GRADE Working Group advises decreasing the grade of the quality of the evidence if the data are “imprecise or sparse”.
  ○ USPSTF: The following questions are considered while grading the evidence :
    – “How many studies have been conducted that address the key question(s)?”
    – “How large are the studies? (i.e., what is the precision of the evidence?) ”
- Biased information. The aggregate risk of bias is contingent upon the risk of bias of the individual studies. In addition to considering methodological limitations of studies, the appropriateness of the study design should also be considered. Correspondence to grading systems:
  ○ EPC SOE: Risk of bias is a required domain. It incorporates the elements of study design and aggregate quality of the studies under consideration.
  ○ GRADE: Study quality and study design are key elements.
  ○ USPSTF: The following questions are considered while grading the evidence:
    – “To what extent are the existing studies of high quality? (i.e., what is the internal validity?)”
    – “Do the studies have the appropriate research design to answer the key question(s)?”
- Inconsistency or unknown consistency. Consistency is the degree to which reported effect sizes from included studies appear to go in the same direction. The two elements are whether effect sizes have the same sign (same side of “no effect”) and whether the range of effect sizes is narrow. However, it should be kept in mind that a statistically significant effect size in one study and an effect size whose confidence interval overlaps null in another study do not necessarily constitute inconsistent results. If there is only one available study, even if considered large sample size, the consistency of results is unknown. Correspondence to grading systems:
  ○ EPC SOE: Consistency is a required domain.
  ○ GRADE: Consistency is a key element.
  ○ USPSTF: The following question is considered while grading the evidence:
    – “How consistent are the results of the studies?”
- Not the right information. There are a number of reasons why identified studies might not provide the right information. First, results from studies might not be applicable to the population and/or setting of interest. Second, the optimal or most important outcomes might not be assessed. Third, the study duration might be too short and patients might not be followed up for long enough duration to adequately assess some outcomes which might be most important. Correspondence to grading systems:
  ○ EPC SOE: Directness is a required domain. It also incorporates the element of surrogate versus clinical outcomes.
  ○ GRADE: Directness is a key element.
  ○ USPSTF: The following question is considered while grading the evidence:
    – “To what extent are the results of the studies generalizable to the general US primary care population and situation? (i.e., what is the external validity?)”

## Characterization of Research Gaps

To further characterize the research gaps we propose using the PICOS framework using the population (P), intervention (I), comparison (C), outcomes (O), and setting (S). Those elements which are inadequately addressed in the evidence base should be characterized. The other relevant elements will be apparent from the key question from which the research is derived. It follows that for research questions that do not relate to a specific key question, all available elements of the research gap should be characterized.

### Population (P)

In this column, team members should be as specific as possible about the age, sex, race/ethnicity, clinical stage, etc. of the population that is not adequately represented in the evidence base. However, it should be recognized that research gaps often do not relate to any specific population but refer to the general population.

### Intervention (I)

In this column, team members should specify the name of the intervention that is inadequately included in the evidence base (generic names of drugs and devices are preferred), the duration of the intervention, its dose, its frequency, who will administer it, etc. As with the population, it may not always be appropriate to specify great detail about the intervention.

### Comparison (C)

In this column, team members should provide the same relevant details about the comparative intervention as for the intervention of interest – name of comparative intervention, its duration, its dose, its frequency, who will administer it, etc. If the comparison is “any other intervention,” this should be indicated. Similarly, if the comparison is “no intervention” or placebo, it should be specified as such. It should also be recognized that there may be instances where there is no specific comparison of interest.

### Outcomes (O)

In this column, team members should specify the relevant outcomes of interest that are inadequately included in the evidence base. It may be appropriate to organize outcomes by type of outcomes or to only list the types of outcomes (e.g., maternal outcomes and fetal outcomes, liver outcomes, and renal outcomes). If appropriate, the timing of outcome assessments that are missing should be specified. If there are no specific outcomes of interest, this should be indicated.

### Setting (S)

In this column, when appropriate, team members should specify the relevant settings for research gaps.

## Special Considerations

Research gaps relating to the accuracy of diagnostic tests can be fit into the PICOS framework by considering the diagnostic test under investigation as the intervention (I) and the gold standard test as the comparison (C). Relevant outcomes (O) in this case could include sensitivity and specificity.

Research gaps relating to the benefit of one form (or frequency) of clinical assessment (e.g., monitoring) versus another can be fit into the PICOS framework by considering these clinical assessments as intervention (I) and comparison (C). The comparison in this case could include a standard form (or frequency) of clinical assessment or no clinical assessment. Relevant outcomes (O) could include clinical outcomes to assess the benefit of the clinical assessment(s).

Research gaps relating to screening tests can be fit into the PICOS framework by considering these tests as intervention (I) and comparison (C). Relevant outcomes (O) could include clinical outcomes to assess the benefit of the screening test(s).

Research gaps which are difficult to characterize into the PICOS framework should be abstracted in free text form. Interventions could potentially include a range of treatment options, order of treatment options, individualization of treatments, etc. These are often gaps for which it is difficult to identify a clear intervention or comparison of interest.

Examples of research questions derived from such research gap s are: “What are the optimal glucose thresholds for medication use in women with gestational diabetes?”; “In what order should patients with cystic fibrosis perform their airway clearance therapies?” and “How should physicians choose an airway clearance therapy for a given patient with cystic fibrosis?”