# Appendix E Step 3: Review of Current Practices of Organizations Involved With Evidence Synthesis—Responses Obtained and Final Determinations of Formal Processes

Sr no. | Country | Organization | Acronym | Question: Do You Have a Formal Process for Identifying Research Gaps? | Question: When Was This Process Initiated? | Question: Please Provide a Description of the Formal Process. | Our Classification of Process
1 | Argentina | Institute for Clinical Effectiveness and Health Policy Australian Safety and Efficacy | IECS | No | - | - | -
2 | Australia | Register of New Interventional Procedures - Surgical | ASERNIP-S | No | - | - | -
3 | Australia | Medical Services Advisory Committee | MSAC | No | - | Comments:; 1. MSAC does not have a formal process for research gap identification.; 2. The closest that MSAC gets is to include comment on level of evidence in its assessment reports.; 3. Where the gap is significant enough to impact on its ability to provide advice it may subsequently alert the MSAC secretariat which will inform the Department.; 4. Neither MSAC nor the Department undertakes specific ‘research’ gap filling on a regular basis.; 5. The closest that MSAC gets to this is to advise that interim funding be considered to allow data capture that could enhance a subsequent MSAC review of public funding. In many instances this is data capture such as utilization numbers and trends managed in the department - not necessarily “research.”; 6. Researchers have independently used MSAC reports and MSAC Public Summary Documents (that provide the rationale for its advice) in order to support applications to research agencies for research funding.; 7. Horizon scanning of new or upcoming technologies is also carried out but through the auspices of AHMAC please see www.horizonscanning.gov.au, In doing this research gaps may again be identified. | -
4 | Australia | Caring for Australasians with Renal Impairment | CARI | Yes | 1999–2000 | 1. Guideline writers are asked to write suggestions for future research when they draft their guidelines. A list of these suggestions is sent to the Australian Kidney Trials Network which is responsible for deciding which research gaps have priority and should be included in their work program.; 2. When a new guideline topic is suggested/needed we perform a literature search and review the results. The steering committee (13 members) assesses which topics have most need of being addressed and match these with lit searches that yield good evidence. | Not formal
5 | Australia | Centre for Clinical Effectiveness | CCE | No | - | - | -
6 | Australia | Joanna Briggs Institute | JBI | Yes | 1996 | The Institute undertakes systematic reviews, both centrally in Adelaide, and through its international collaboration of 65 centers located on every continent. These reviews are published and loaded in an online library for access. As systematic reviews examine the published literature related to a particular intervention or outcome, reviews are also able to identify strengths and weaknesses as well as knowledge gaps in the underlying primary research base. In conducting systematic reviews, the Institute uses a standardized approach based on methodological criteria for quality, transparency and methodological rigor. For each review published, this includes a detailed analysis and commentary on the gaps in the primary research that were identified during the conduct of the systematic review. Each review undertaking through the collaboration is required to include a section that describes specific gaps in the research literature and provide some commentary on these gaps and how they might be addressed. When published, these are available to primary researchers and organizations internationally. The institute also publishes a monograph series that includes reports that specifically focus on the gaps identified by systematic reviews. This is an occasional series as our primary approach is via the relevant sections of the systematic review report. | Not formal
7 | Austria | Gesundheit Österreich GmbH | GÖG | No | - | - | -
8 | Austria | Ludwig Boltzmann Institut für Health Technology Assessment | LBI of HTA | No | - | - | -
9 | Canada | Agence d’évaluation des technologies et des modes d’intervention en santé (Québec Government Agency responsible for Health Services and Technology Assessment) | AETMIS | No | - | [underlined: Comments:] Our organization does not have any formal process for identifying research gaps. In our HTA reports we do often identify research gaps, but there is no formal process in place. | -
10 | Canada | Canadian Agency for Drugs and Technologies in Health | CADTH | Yes | Not yet | Please note that our organization is currently undergoing an internal reorganization, bringing together what used to be 3 distinct HTA-like programs. Over the course of the next year, we will be “harmonizing” our processes – with the likely end goal that the process for identifying research gaps/needs that existed in one of these programs (the COMPUS program) will be applied across the organization. The link to CADTH’s COMPUS process is as follows: http://www.cadth.ca/index.php/en/compus/process/summary The output of the gaps and key messages” component of the process is a document that provides a “gap analysis;” this report is published on our website, may be published in peer- reviewed journals and (as of right now) shared in a more informal manner with our national health services research funding body, CIHR.Also note that Canada now has the “Drug Safety & Effectiveness Network” (DSEN) that is funded by Health Canada, and located at the Canadian Institutes for Health Research (CIHR). This network is in its infancy, so the mechanisms by which research gaps/needs are identified & addressed are still being elucidated. It is also important to note that this network considers only drugs/pharmaceuticals; the other facets of health care are not covered. For more information on DSEN, please see: http://www.cihr.ca/e/40269.html | Not formal
11 | Canada | Institute of Health Economics | IHE | No | - | [underlined: Comments:] “Published and article, “Using HTA to Identify Research Gaps: A Pilot Study”, in ‘Health Policy’ in 2008 based on this work.” | -
12 | Canada | Medical Advisory Secretariat | MAS | No | - | [underlined: Comments:] Our HTA process is application driven, or through requests from the Minister of Health office. | -
13 | Canada | Program in Evidence-based Care | PEBC | Yes | 1995 | PEBC is a guideline development organization located within the academic environment of McMaster University and funded by the Ontario Ministry of Health through Cancer Care Ontario. From the inception of the program in 1995, topics for guideline development have been put forward by our clinical partners who are practicing clinicians in the cancer care delivery system in Ontario. The impetus to begin a new PEBC guideline project may come from an existing Disease Site Group/Guideline Development Group (DSG/GDG), CCO Clinical Programs or Executive Team, the Ontario Ministry of Health and Long Term Care or other stakeholders in the Ontario cancer system. Some common criteria used to set priorities include the burden of disease, emergence of new care options, unwanted variation in clinical practice, opportunity to improve quality of care, safety or system performance, and new evidence. | Formal process for setting priorities for guideline development. [underlined: Organizing Principle:] None identified
14 | Finland | Finnish Office for Health Technology Assessment | FinOHTA | Yes | Jan-10 | We have three separate pathways 1. Rapid reviews, which we are doing in co- operation with Finnish hospital districts (n=20). The representatives of the hospital districts form a committee, which is supposed to feed FinOHTA with information needs. We get suggestions for new evaluation technology with a mini- HTA questionnaire (attached). Finohta’s MUMM (Managed Uptake of Medical Methods) group scopes the suggested technology and the committee chooses 5–10 technologies to be evaluated per year. When review is finished, the information gaps are identified separately and listed in the conclusion of the report. Reports are available in Finnish only (Summaries in English).2. Screening program. The secretariat for the Screening Committee of the Ministry of Health is in FinOHTA, and FinOHTA is supposed to asses all screening programs the Committee requires. Secretariat prepares a full HTA and gives a detailed presentation with experts for the screening group before the decision to evaluate the program is made. Research gaps are identified separately and presented. The Committee may decide that before a screening program is launched nationally, the missing information shall be collected through a pilot program. For example, currently a pilot study on screening colorectal cancer is collecting data about willingness to participate, effectiveness, and feasibility of organizing the screening in different areas.3. FinOHTA also prepares full HTA reports. Anybody can suggest a topic for evaluation. FinOHTA scopes the topic and decision to make a full HTA is made by our scientific committee of external experts. The decision is based on a structured evaluation of relevance. The decision to make a report is not dependent on information about evidence gaps. If gaps are identified during the HTA process, they are presented as part of the formal summary of the document. | Not formal
15 | France | Haute Autorité de Santé | HAS | No | - | [underlined: Comments] Our organization may indeed identify evidence gaps when assessing health technologies and may recommend additional evidence generation. Following our recommendations, additional trials, studies or registries can be required by decision makers. These requirements may either be included in the agreement with manufacturers during pricing negotiations or be included within a conditional reimbursement framework. Additional studies may be required for all types of technologies. Nevertheless, we don't have a formal process for identifying research gaps/needs. | -
16 | Germany | German Agency for HTA at the German Institute for Medical Documentation and Information | DAHTA@DIMDI | No | - | - | -
17 | Israel | Israel Center for Technology Assessment in Health Care | ICTAHC | No | - | - | -
18 | Italy | HTA Unit in A. Gemelli Teaching Hospital | UVT | Yes | September, 2006 | (NOTE: This date is referred to the “gap assessment procedure” start, the procedure of overcoming the evidence gap is still informal)Unità di Valutazione delle technology (UVT -HTA Unit) active at “A. Gemelli” University Hospital has been involved in HTA at Meso levels for about ten years, to support decisions making process regarding the introduction into clinical practices of new health technologies. According to a formal procedure, the staff of UVT advise the hospitals management in difficult resource allocation decisions, using an approach based on scientific technology assessments through the formulation of recommendation. The procedure starts from a request of a new medical technology (innovative, high cost and not yet used into hospital clinical practice) by a clinical department. The results of evaluation activity are assessment reports in which are considered all the relevant topics for an hospital context (decryption of the technology, regulatory status, systematic review of the evidence, alternatives and economics’ issues). In the figure 1 are reported the phases of the assessment procedure, particularly UVT manages directly the IInd, IIIrd, IVth phases. Frequently, because of the evaluated technologies are really innovative we point out a scarcity of evidence on which basis to formulate a recommendation. When we observed the lack of evidence we plan a meeting with referral clinicians, pharmacy unit, administrative unit in order to evaluate the possibility to elaborate an observational protocol for testing the new medical technology and to implement a phase of practice trial. During the meeting with clinician we define the specific clinical end points to investigate in the real hospital’s context treating real patients. Those end points are specified in a procedure of testing (the test isn’t a very clinical study) in which are established also the temporal range of observation. Instead during the meeting with pharmacy and administrative offices we consider the modality of introduction of restricted use of technology (e.g., for payments topic for free or limited in number). | Not formal
19 | Lithuania | State Health Care Accreditation Agency under the Ministry of Health of the Republic of Lithuania | VASPVT | No | - | - | -
20 | Malaysia | Health Technology Assessment Section, Ministry of Health Malaysia | MaHTAS | No | - | - | -
21 | Mexico | Centro Nacional de Excelencia Tecnológica en Salud | CENETEC | No | - | [underlined: Comments:] From February 2006 a project to gradually building a priority-setting methodology for complex diseases to be eventually covered by the resources Catastrophic Expenses Fund was developed by the Mexican Ministry of Health towards the General Health Council. The most recent version of the methodology started operations in February 2008. CENETEC participates in working groups in developing a studies and discussions to evaluate clinical, economic, ethical and social acceptability criteria inherent to the set of complex diseases identified as candidates for gradual coverage. Quantitative and qualitative methods are used during the evaluation. As an HTA agency, we seek to inform decisionmaking by examining the effects of a particular technology with respect to its safety and effectiveness as well as its social, economic and ethical implications that allow to prioritize interventions that would help to achieve the Health Goals in the country. | -
22 | New Zealand | Health Services Assessment Collaboration | HSAC | Yes | 2007 | Health Services Assessment Collaboration (HSAC, in association with Health Technology Associates, Sydney) conducts health technology assessments and systematic reviews as a way to determine effectiveness of health care interventions and services. The context of these appraisals are framed by the target population, the intervention or set of interventions under consideration, the comparator (either usual care process, or another alternative technology, or a specified population group based on the research question), and the defined measurable health outcomes. For HSAC, identification of the research gaps is a two-step process. In the first step, the research needs are identified by health care professionals throughout New Zealand and are submitted to the Ministry of Health. HSAC discusses these proposals with the officials in a prioritization meeting in order to decide the relative importance and rank order the relevance and applicability of these proposals. Once the proposals are finalized for review and further research, HSAC researchers initiate the step two for identifying the specific research gaps within the “accepted” proposals. This is done through the process of initially developing a “scoping protocol” for each research project by defining the research question, and identifying the population, intervention, comparator, and outcomes for each research project for defining the research need. During this process, the scoping protocols are referred back to the clients (those who requested the specific reviews or health technology assessments in the first place). This is a consensus driven iterative process. Once the research gaps are thus identified, and the question for the review is finalized, the review process ensues. | Formal process for setting priorities for systematic reviews and HTAs [underlined: Organizing Principle:] PICO
23 | Spain | Agencia de Evaluación de Tecnologias Sanitarias | AETS | No | - | - | -
24 | Spain | Catalan Agency for Health Information, Assessment and Quality | CAHIAQ | Yes | 1996 | The Catalan Agency for Health Information, Assessment and Quality (CAHIAQ), formerly the Catalan Agency of Health Technology Assessment and Research (CAHTA), efforts to identify knowledge gaps are addressed to priority setting for research/assessment of health services, the identification of effective interventions and the field of applied translational research. In particular, CAHIAQ has been ruling every two-years a Call for Topics among the regional decision-making and scientific community, which subsequently are submitted to a Priority-setting process to identify a number of prioritized topics for which the CAHIAQ Research Call on applied health research is subsequently launched. This process is being done to be accountable with CAHIAQ mission to identify knowledge gaps provide scientifically- based information to regional healthcare decision makers. | Formal process for identifying primary research gaps/needs. [underlined: Organizing Principle:] None identified
25 | Sweden | The Swedish Council on Technology Assessment in Health Care | SBU | Yes | November, 2009 | We have just started a project on identifying knowledge gaps. The project is a mandate from the Ministry of Social Affairs. Our aim is to delineate uncertainties that cannot be answered with reference to reliable and up-to-date systematic reviews explicit and actively disseminate knowledge about which treatments that are not sufficiently evaluated. We have formed a steering group with representatives from various stakeholders who can give us input into the work. Our first task is to build a database of uncertainties. | Not formal
26 | Switzerland | Medical Technology Unit - Swiss Federal Office of Public Health | MTU-SFOPH | No | - | - | -
27 | Taiwan (China) | Center for Drug Evaluation | CDE | No | - | - | -
28 | The Netherlands | The Medical and Health Research Council of The Netherlands | ZonMw | Yes | 1998 | Government ministries, the Netherlands Organization for Scientific Research and other organizations commission ZonMw to find solutions to certain problems or to boost work in particular areas. Together with experts from the field, ZonMw analyses the current state of play, the problems that exist, the priorities and where to look for solutions. We then incorporate our findings into a program – a plan of action that sets out the direction for developments in scientific research and health care. The programme gives scientific and health care institutions the opportunity to conduct research or to develop, test and implement innovations on a project basis. ZonMw’s main commissioning bodies are the Ministry of Health, Welfare and Sport and Netherlands Organization for Scientific Research. In other words, identification of research gaps is a constant part of our program development strategy. Process and methods used depend on the topic and area, and could include literature review, field research, expert/focus group and other kinds of meetings, interviews. In some cases extensive scientific research is being commissioned. | Not formal
29 | UK | NIHR Coordinating Centre for Health Technology Assessment | NETSCC, HTA | Yes | 1993 | Since the HTA programme commenced funding in 1993, identification and prioritization has formed a major aspect of the commissioning workstream. As the programme has expanded, the need for greater expansion in the identification of topics has arisen and a formalized identification team started in 2005. Similarly, as NETSCC now manages 5 programmes, there is a need to feed topics across all 5 research programmes. Topics are suggested via a web-based form, via panel members, panel researchers and through working with external agencies. These topics are all checked by the consultant advisors for their remit including whether there is an NHS need and also go through a series of panels (with clinicians, academics present) to decide relevance to the NHS. Since our restructure earlier this year, we have a newly formed Identification Team that is working towards establishing a NETSCC wide strategy for identification of topics. | Not formal
30 | UK | National Horizon Scanning Centre | NHSC | No | - | - | -
31 | UK | National Institute for Health and Clinical Excellence | NICE | Yes | Unknown | 9.5 Formulating research recommendations The GDG is likely to identify areas in which there are uncertainties or where robust evidence is lacking. This section provides a framework for highlighting these uncertainties and translating them into research recommendations. Advice is also given about identifying “high-priority” research recommendations for inclusion in the NICE version of the guideline. Research recommendations can cover questions about any aspect of the guidance and are designed to address uncertainties that have been identified. Examples include clinical or cost effectiveness, implementation, outcomes, equality issues, the accuracy of a test, diagnosis, prognosis, rates of harm or other events, patients’ experience, measurements of outcome, and service delivery and organization. Primary research or secondary research (for example, systematic reviews) can be recommended. 9.5.1 Principles for formulating research recommendations Research recommendations should be formulated as questions. A section that includes the questions requiring further research should be included as an appendix to the full guideline. These research questions may also be highlighted in individual chapters. Each research question should relate to an uncertainty or evidence gap that has been identified during the guideline development process. Each research recommendation should be formulated as an answerable question or a set of closely related questions. This should use the PICO (patient, intervention, comparison and outcome) framework. 9.5.2 Selecting high-priority research recommendations for the NICE guideline To help ensure that research addresses key areas, for a standard clinical guideline the GDG should select up to five high-priority research recommendations to include in the NICE version of the clinical guideline. These should be identified using the criteria in table 9.2. Each high-priority research recommendation should be summarized in a single paragraph (ideally no longer than 150 words) that describes why the proposed research is important (for an example, see box 9.5). The reasons for selecting each high-priority research recommendation should be presented in a table in an appendix to the full guideline, using table 9.2 as a template, and indicating if any information is unavailable. The high-priority research recommendations for each clinical guideline will be posted on the NICE website3. They will then go through a second prioritization process within NICE that considers all research recommendations relating to all types of guidance produced by NICE. | Formal process for identifying primary research gaps/needs as well as setting priorities for systematic reviews. [underlined: Organizing Principle:] PICO
32 | UK | Royal College of Nursing | RCN | No | - | [underlined: Comment:] Whilst we do not have a current organization-wide system for identifying research priorities we have undertaken a number of processes over the years to identify gaps in professional nursing knowledge / nursing research priorities. These can be found here http://www.rcn.org.uk/development/researchanddevelopment/policy/priorities In addition we are in the process of implementing a new organization wide research strategy and as a consequence of recommendation no 6, we are revising our research governance and management arrangements. This will enable us to develop an implement an organization wide research priority setting process. Your survey is therefore timely and I look forward to reading your final report. With best wishes. | -
33 | UK | Scottish Intercollegiate Guidelines Network | SIGN | Yes | Unknown | Guideline Development Groups (GDGs) establish a set of key questions to form the basis of a guideline. Evidence is gathered and reviewed for each of these questions. If a question is seen as particularly important and there is no evidence, or only such poor evidence that the GDG does not feel able to make a recommendation, then a recommendation for further research will be made. These recommendations are included in published guidelines. Research grants in the National Health Service in Scotland are made by the Chief Scientists Office, who has a formal process for rating grant applications. A grant proposal specifically linked to a recommendation for research in a SIGN guideline will get additional points in the scoring system. We are also planning to contribute to the DUETS database (http://www.library.nhs.uk/duets/) which is intended as a source of research topics in health care for across the UK. | Formal process for identifying primary research gaps/needs. [underlined: Organizing Principle:] Key question
34 | US | American Academy of Otolaryngology - Head and Neck Surgery Foundation | AAO-HNS | Yes | Unknown | The American Academy of Otolaryngology—Head and Neck Surgery (AAO-HNS) Foundation identifies research gaps/needs through a variety of avenues including clinical practice guidelines, AAO-HNS Research Advisory Board (RAB), and the Centralized Otolaryngology Research Efforts (CORE) Grant Program.; 1. Clinical practice guidelines developed at the AAO-HNS are based on systematic literature reviews on a particular topic. A “Research Needs” section is developed by the guideline panel that identifies gaps and needs after evaluation of the literature.; 2. The AAO-HNS RAB consists of 12 officers, including both AAO-HNS members and nonmember stakeholders active in otolaryngology research. The RAB provides a voice for otolaryngology research needs and partnership opportunities of the community at large.; 3. In an effort to strengthen research support in all areas of otolaryngology, the AAO-HNS Foundation has joined forces with several senior societies, foundations and sponsors to broaden research opportunities, and to streamline and enhance the research application and review process. CORE serves as a central clearinghouse and facilitator for otolaryngology-head and neck surgery research programs. The research funded by CORE may lead to further identification of research needs. | Not formal
35 | US | Center for International Rehabilitation | CIR | No | - | - | -
36 | US | National Kidney Foundation | NKF | Yes | 1997 | In each of our guideline development projects, we identify the development of research recommendations as a goal. Workgroup members are asked to formulate recommendation for future research towards the end of the guideline development process based on what kind of research would help fill evidence gaps that were encountered in the systematic reviews conducted for the guidelines and in the formulation of the recommendations. Criteria for recommending future research are that this research should either address a question that would directly inform and area of clinical practice that is currently unaddressed or a question that would make the evidence base underpinning a weak recommendation more definitive. The workgroup members are prompted to use the PICOD format for defining populations, interventions (or predictors), comparators, outcomes and time points for outcome measurement. The workgroup is also asked to prioritize the research recommendations across the topics in the guideline. Describe how the research recommendations in the guidelines are then used for the RFAs for KDOQI research grants as competitions in a research initiative designed to stimulate investigation addressing the research recommendations that accompany the Kidney Disease Outcomes Quality Initiative (KDOQI) guidelines. The topics for this Request for Application (RFA) were selected by the KDOQI Research Advisory Committee based upon the following criteria:; - Areas that are ripe for study, i.e., where there is a gap in knowledge but there is some preliminary evidence suggesting that research could be fruitful;; - Impact on patient outcomes;; - Likelihood that meaningful progress on the research topic could be generated at the level of NKF support;; - Interest of policymakers (Congress, CMS, FDA);; - Likelihood that investigator may be able to secure funding (from NIH or industry) to complete the study, or take the next steps towards improving patient outcomes.; Answering the research recommendation questions will enable KDOQI to provide more authoritative guidance regarding appropriate tests and therapies in the future, lead to enhanced patient outcomes, advance patient advocacy and, ultimately, validate, critique, and improve guidelines. As a result, this research program should also contribute to the effective utilization of KDOQI guidelines and clinical practice recommendations. | Formal process for identifying primary research gaps/needs. [underlined: Organizing Principle:] PICOD
37 | US | VA Technology Assessment Program | VATAP | No | - | - | -

Abbreviations: AHMAC=Australian Health Ministers Advisory Council, CMS=Center for Medicare and Medicaid Services, CCO=Cancer Care Ontario, COMPUS=Canadian optimal medication prescribing & utilization service, CORE=centralized otolaryngology research efforts, DSEN=drug safety & effectiveness network, DUETS=database of uncertainties about the effects of treatments, FDA=Food and Drug Administration, GDG=guideline development group, GmBH=gesellschaft mit beschränkter haftung, HTA=health technology assessment, KDOQI=kidney disease outcomes quality initiative, MUMM=managed uptake of medical methods, NIH=National Institutes of Health, NIHR=National Institute for Health Research, PICO=population, intervention, comparison, and outcomes, RAB=research advisory board, RFA=request for applications, UK=United Kingdom, US=United States, VA=veterans affairs.