# Appendix D Step 3: Review of Current Practices of Organizations Involved With Evidence Synthesis—List of Contacted Organizations

Sr No. | Country | Organization | Acronym | Activities
1 | Argentina | Institute for Clinical Effectiveness and Health Policy | IECS | HTA
2 | Australia | Adelaide Health Technology Assessment | AHTA | HTA
3 | Australia | Australian Safety and Efficacy Register of New Interventional Procedures -Surgical | ASERNIP-S | HTA
4 | Australia | Medical Services Advisory Committee | MSAC | HTA
5 | Australia | Caring for Australasians with Renal Impairment | CARI | systematic reviews
6 | Australia | Joanna Briggs Institute | JBI | systematic reviews
7 | Australia | National Breast and Ovarian Cancer Centre | NBOCC | systematic reviews
8 | Australia | Centre for Clinical Effectiveness | CCE | systematic reviews, HTA
9 | Austria | Gesundheit Österreich GmbH | GÖG | HTA
10 | Austria | Ludwig Boltzmann Institut für Health Technology Assessment | LBI of HTA | HTA
11 | Belgium | Belgian Health Care Knowledge Centre | KCE | HTA
12 | Brazil | Secretaria de Ciência, Tecnologia e Insumos Estratégicos, Departamento de Ciência e Tecnologia | DECIT-CGATS | HTA
13 | Canada | Agence d’évaluation des technologies et des modes d’intervention en santé (Québec Government Agency responsible for Health Services and Technology Assessment) | AETMIS | systematic reviews, HTA, CEA
14 | Canada | Canadian Agency for Drugs and Technologies in Health | CADTH | HTA
15 | Canada | Institute of Health Economics | IHE | HTA
16 | Canada | Medical Advisory Secretariat | MAS | HTA
17 | Canada | Program in Evidence-based Care | PEBC | systematic reviews
18 | Chile | Department of Quality and Patient Safety of the Ministry Health of Chile | ETESA | HTA
19 | Denmark | Danish Centre for Evaluation and HTA | DACEHTA | HTA
20 | Denmark | Danish Institute for Health Services Research | DSI | HTA
21 | Finland | Finnish Office for Health Technology Assessment | FinOHTA | HTA
22 | France | Comité d’Evaluation et de Diffusion des Innovations Technologiques | CEDIT | HTA
23 | France | Haute Autorité de Santé | HAS | HTA
24 | Germany | German Agency for HTA at the German Institute for Medical Documentation and Information | DAHTA@DIMDI | HTA
25 | Germany | Institut für Qualität und Wirtschaftlichkeit im Gesundheitswesen | IQWiG | HTA
26 | International | International Network of Agencies for Health Technology Assessment | INAHTA | HTA
27 | Ireland | Health Information and Quality Authority | HIQA | HTA
28 | Israel | Israel Center for Technology Assessment in Health Care | ICTAHC | HTA
29 | Italy | HTA Unit in A. Gemelli Teaching Hospital | UVT | HTA
30 | Italy | The Agency for Regional Healthcare | Age.na.s | HTA
31 | Korea | Committee for New Health Technology Assessment | CNHTA | HTA
32 | Lithuania | State Health Care Accreditation Agency under the Ministry of Health of the Republic of Lithuania | VASPVT | HTA
33 | Malaysia | Health Technology Assessment Section, Ministry of Health Malaysia | MaHTAS | HTA
34 | Mexico | Centro Nacional de Excelencia Tecnológica en Salud | CENETEC | HTA
35 | New Zealand | Health Services Assessment Collaboration | HSAC | HTA
36 | Norway | Norwegian Knowledge Centre for the Health Services | NOKC | HTA
37 | Poland | Agency for Health Technology Assessment in Poland | AHTAPol | HTA
38 | Spain | Agencia de Evaluación de Tecnologias Sanitarias | AETS | HTA
39 | Spain | Andalusian Agency for Health Technology Assessment | AETSA | HTA
40 | Spain | Basque Office for Health Technology Assessment | OSTEBA | HTA
41 | Spain | Catalan Agency for Health Information, Assessment and Quality | CAHIAQ | HTA
42 | Spain | Galician Agency for Health Technology Assessment | AVALIA-T | HTA
43 | Spain | Unidad de Evaluación de Tecnologías Sanitarias | UETS | HTA
44 | Sweden | The Swedish Council on Technology Assessment in Health Care | SBU | HTA
45 | Switzerland | Medical Technology Unit - Swiss Federal Office of Public Health | MTU-SFOPH | HTA
46 | Taiwan (China) | Center for Drug Evaluation | CDE | HTA
47 | Thailand | Health Intervention and Technology Assessment Program | HITAP | HTA
48 | The Netherlands | College voor Zorgverzekeringen | CVZ | HTA
49 | The Netherlands | Gezondheidsraad | GR | HTA
50 | The Netherlands | The Medical and Health Research Council of The Netherlands | ZonMw | HTA
51 | UK | Centre for Reviews and Dissemination | CRD | systematic reviews, HTA, CEA
52 | UK | NIHR Coordinating Centre for Health Technology Assessment | NETSCC, HTA | HTA
53 | UK | National Horizon Scanning Centre | NHSC | HTA
54 | UK | National Institute for Health and Clinical Excellence | NICE | systematic reviews, HTA, CEA
55 | UK | Quality Improvement Scotland | QIS | HTA
56 | UK | Royal College of Nursing | RCN | systematic reviews, CEA
57 | UK | Scottish Intercollegiate Guidelines Network | SIGN | systematic reviews
58 | US | American Academy of Otolaryngology - Head and Neck Surgery Foundation | AAO-HNS | systematic reviews
59 | US | American College of Physicians | ACP | systematic reviews, HTA
60 | US | American Society of Clinical Oncology | ASCO | systematic reviews
61 | US | American Urological Association | AUA | systematic reviews, HTA
62 | US | Center for International Rehabilitation | CIR | HTA
63 | US | National Kidney Foundation | NKF | systematic reviews
64 | US | VA Technology Assessment Program | VATAP | HTA

Abbreviations: CEA=cost-effectiveness analysis, GmBH=gesellschaft mit beschränkter haftung, HTA=health technology assessment, NIHR=National Institute for Health Research, UK=United Kingdom, US=United States, VA=veterans affairs.