# Appendix C Step 2: Review of Current Practices of Evidence-based Practice Centers (EPCs)—Responses Obtained From EPCs

EPC # | EPC Name | Title of Evidence Report (Ref No.) | Question: Did You Use a Specific Framework or Method To Identify Research Gaps? If so, Please Describe the Method Below. | Question: Do You Have Any Corrections or Clarifications on What Was Abstracted? If so, Please List Them Below. | Question: Have You Implemented a Different Process Since Publishing the Above- Mentioned Report? If so, Please Provide a Description of the Process, and Indicate When it Was Implemented.
1 | Blue Cross and Blue Shield Association | HER2 testing to manage patients with breast cancer or other solid tumors6 | No | I am not sure what you mean in your table by “were research gaps defined?” We did not define the term research gap, but we did identify specific research gaps through the report. They were often embedded in the test or implicit, however. For example, when a key question cannot be answered because of poor or heterogeneous evidence, it is implicit that a research gap exists; see, e.g., the conclusions to key question 5 on p. 155. That being said, having a more explicit list of research gaps would be useful and advisable. Much of the weakness of the evidence in this report had to do with methodological issues. For example, did studies that relied on banked samples from prior RCTs adequately address the issue of missing samples and any bias that might result (e.g., was the percentage of HER2 positive patients similar in both arms of the trial for which there were samples?). Also, few studies used appropriate multivariable analysis and then tested for an interaction terms between HER2 status and treatment group. The description of the methods used was often scanty and precluded determination of whether this has been done. Therefore, much of Chapter 4, Discussion and Future Research, focused on these methodological issues that greatly undermined confidence in the existing studies. | We have not adopted a specific framework like PICOS in more recent completed repots, but we have become more explicit in grading the quality of evidence for each key question (implicitly indicating where the research gaps exist) and in providing a concise list of research recommendations. This change began with the CER on radiotherapy techniques in head and neck cancer, the report that followed HER2 and was recently released publicly. With AHRQ’s emphasis in the ARRA work and our pilot project on future research on treatments for localized prostate cancer, we are developing explicit lists of research gaps, organized using PICOS, and recommended research, and relying on a multidisciplinary panel to rank them.
2 | Duke University EPC | Effectiveness of assisted reproductive technology7 | No, we didn’t use a specific framework or methodology. The general approach to identifying research gaps for the reports has been to summarize (1) the existence of relevant literature addressing the key questions (a major problem for many women’s health issues), and (2) methodological issues in the existing literature which contribute to uncertainty. Within the range of research gaps identified for a particular question, we have not used any formal methods for prioritization. | The abstraction appears correct. | No
3 | Johns Hopkins University EPC | Impact of gene expression profiling tests on breast cancer outcomes8 | No | No | No
4 | McMaster University EPC | Complementary and alternative medicine in back pain utilization report9 | This question was not included (a framework was identified). | The summary above is generally correct. You raise an excellent point regarding specifying what is or is not a “research gap.” It will be interesting to see how others identify these. | We do not seem to be consistent across reviews in the location or methods of reporting research gaps, other than consistently locating these within the discussion.
5 | Oregon EPC | Barriers and drivers of health information technology use for the elderly, chronically ill, and underserved10 | The authors presented an analytic framework for separating research questions (and studies) into 5 categories. Many studies focused on the earlier relationships in the model (Patient Characteristics, Environment, and Technology influencing the use of Health IT). Other studies had information on the subsequent relationship between Health IT use and process outcomes (health behaviors, self- efficacy, physiological measures). There were very few studies that looked at the final outcomes of quality-of-life, satisfaction, and costs. The lack of information in existing studies to answer each of the component research questions, with respect to the elderly, underserved and chronically ill, defined the research gap. In addition, many gaps/issues arose as we reviewed the material (e.g., need is for a principled taxonomy of interactive Health IT interventions, best practices for the design and implementation, etc.). Finally, there were summaries at the end of the analysis of each research question. These summaries usually identified that there was insufficient research in that area on disadvantaged populations, such as minorities, low-income groups, elderly, disabled, and geographically remote populations. | Yes. The information included in a table is as follows:; - Were research gaps defined? Ch. 5 described and defined the research gaps. In addition, at the end of the summary of each of the 5 research questions, unanswered questions were identified.; - Was there a description of how research gaps/needs were identified? The lack of information in existing studies to answer each of the component research questions from the analytic framework, with respect to the elderly, underserved and chronically ill, defined the research gap. In addition, many gaps/issues arose as we reviewed the material (e.g., need is for a principled taxonomy of interactive Health IT interventions, best practices for the design and implementation, etc.).; - Was there an explicit framework/set of organizing principles (e.g., PICO, a diagram) used for the identification of research gaps/needs? The authors presented an analytic framework for separating research questions (and studies) into 5 categories. Many studies focused on the earlier relationships in the model (Patient Characteristics, Environment, and Technology influencing the use of Health IT). Other studies had information on the subsequent relationship between Health IT use and process outcomes (health behaviors, self-efficacy, physiological measures). There were very few studies that looked at the final outcomes of quality-of-life, satisfaction, and costs. The lack of information in existing studies to answer each of the component research questions, with respect to the elderly, underserved and chronically ill, defined the research gap.; - Were future research gaps/needs provided, and where were they found? Ch. 5 described and defined the research gaps. In addition, at the end of the summary of each of the 5 research questions, unanswered questions were identified. There was an additional section in the Executive Summary describing research gaps.; Executive Summary Research Gaps: Questions remain as to (a) the optimal frequency of use of the system by the patient, which is likely to be condition-specific; (b) the optimal frequency of use or degree of involvement by the health professionals; (c) whether their success depends on repeated modification of the patient’s treatment regimen or simply ongoing assistance with applying a static treatment plan. However, it is clear that the consumer’s perception of benefit, convenience and integration into daily activities will serve to facilitate the successful use of the interactive technologies for the elderly, chronically ill, and underserved. Perhaps most challenging, these systems shift the locus of care away from traditional physician office visits, and many of them involve the participation of a multidisciplinary health care team; these activities are difficult to support financially under current episode-based, fee-for-service health care reimbursement mechanisms. Chapter 5 Research Gaps: In our review of the evidence on the barriers and drivers of the use of interactive consumer health IT by the elderly, chronically ill, and underserved populations we identified several areas for future work. The most pressing need is for a principled taxonomy of interactive consumer health IT and related interventions, so that the resulting outcomes of studies involving these systems can be better interpreted by understanding effects of the various components. Currently, it is difficult to generalize across the wide variety of systems. Similarly, future research is needed to understand best practices for the design and implementation of these interactive health technologies for patients. A clear taxonomy will facilitate this effort. In addition to standardizing our descriptions of the variety of interactive consumer health IT applications, it will be important to develop standardized and clear definitions of the intermediate outcomes relating to the use of these technologies. For example, in the studies we reviewed, system usage has been measured by logins, Web clicks, or time within a session. These varied measures, along with differing expectations for use for each system, make it difficult to compare usage between systems in a meaningful way. The issue gains relevance as the field strives to determine if the measurement of the health technology usage can serve as a means of determining individual engagement, activation, or preference, and whether it can serve as a proxy for intervention exposure or “dose.” Finally, there is a paucity of research with direct comparison of the use and outcomes of these technologies by the general population versus disadvantaged populations, such as minorities, low-income groups, elderly, disabled, and geographically remote populations. It would be very useful to test the same technology, protocol, and implementation interventions with comparison populations within the same study, to truly understand the barriers and drivers associated with these interventions. Summary at the end of each Research Question: These summaries usually identified that there was insufficient research in that area on disadvantaged populations, such as minorities, low-income groups, elderly, disabled, and geographically remote populations. | No
6 | RTI International - UNC EPC | Outcomes of maternal weight gain11 | No, we didn’t have a formal framework that we used. Informally, we used the “limitations of the evidence base” section to identify methodological areas for future research and the key questions to identify areas for future research for content-specific topics. | No | I think that we are continuing to use the two-step process described above – that is, we use the methods limitations to construct methodological areas for improvement, and the key questions to identify content-specific areas for future research. One change is that the PICOS framework has been more rigorously applied in each generalist review (they are already embedded in our CERs), so the questions and the areas for future research in our generalist reviews might reflect PICOS better now that they had in the past. Having said that, we are not explicit in our use of PICOS for the future research needs section. Another change is that we now include a summary of strength of evidence in the discussion chapter for generalist reviews that shows where there is no evidence (or insufficient evidence) so it’s more apparent to the reader where we came up with the content-specific gaps.
7 | Southern California/ RAND EPC | Bariatric surgery in women of reproductive age: Special concerns for pregnancy12 | I’m not sure a specific “framework” is needed. We were given key questions to investigate, included PICOS. If no evidence is found to address a specific issue / PICO, and no studies are underway to address the issue, then clearly a research gap exists. Same goes for if only low quality evidence exists. We usually run the “future research” suggestions by the TEP for input and additional suggestions. We can certainly add a few sentences in future reports on the process. However, this is not rocket science. I don’t think we need to waste resources (i.e., tax dollars) creating some fancy algorithm or official process. | Again, I never found it necessary to define the term “research gap” because I felt it was more than obvious to the reader. | No, same process as listed above. Again, we could add a one paragraph description to the methods section of future reports. We do look at each key question, population, intervention, and outcome to see where research gaps exist. This can easily be done with an excel table; I don’t think we need to spend a lot of time creating some complex process.
8 | Tufts University EPC | Vitamin D and calcium: A systematic review of health outcomes13 | Please see answer to next question. | Vitamin D and Calcium: Systematic Review of Health Outcomes report was not a good example of typical AHRQ evidence reports that would represent that practices of our center used to identify or present research gaps. This report was commissioned to support the development of Dietary Reference Intake (DRI) values. DRIs are the nutrient reference values issued by the Institute of Medicine (IOM) of the National Academy of Sciences and we followed a previously established framework which was designed to facilitate the decision-making process of an expert panel of IOM. For this reason, there was no typical “ Future Research” section in this report. One of the objectives of this report was to help IOM panel to identify research gaps deriving vitamin D and calcium DRIs. We therefore produce three grand overview tables (similar to evidence map) mapping the amount of data available according to PICO criteria (please see Table 1–3 in the report). The empty areas represent the areas need future research. We also made several suggestions for future DRI committees. Given the nature of this special evidence report, I would also consider this section as “Future Research” section in a typical evidence report. If you would accept above arguments, I would suggest change some information you extracted as follows (highlighted in yellow):; - Were research gaps defined? yes; - Was there an explicit framework/set of organizing principles (e.g., PICO, a diagram) used for the identification of research gaps/needs? Yes (Table 1–3); - Were future research gaps/ needs provided, and where were they found? Yes, Table 1–3 and in the last section of Chapter 4. How were research gaps/needs presented? Tables and texts. | This report was not a typical evidence report. Please see more details in previous question.
9 | University of Alberta EPC | Diabetes education for children with type 1 diabetes mellitus and their families14 | No | The summary accurately reflects our approach and presentation. | We don’t have a process in place regarding the research/gaps needs section.
10 | University of Minnesota EPC | Integration of mental health/substance abuse and primary care15 | We used the discovery process that is inherent in the review process. If a question is difficult to answer with the given literature, it becomes apparent. Since there is generally always more research that can be done, we generally try to keep to the research gaps that are more pressing, rather than be exhaustive. It is also not uncommon to have research gaps arise during conversations with TEP members. These are also usually noted and incorporated into the discussion section. | The organizing framework was the key questions themselves. | We have not implemented a different process. There has not yet been the need.
11 | University of Ottawa EPC | Diagnosis and treatment of erectile dysfunction16 | We used implicit (not explicit) framework to identify research gaps across PICO which was based on the analytic framework (page 18 of the report). The guiding principle was the degree to which a given research question was addressed by the identified evidence. This degree depended on an informal summary of constituent elements of strength of the reviewed evidence such as individual study quality, presence/absence of evidence, amount of evidence, consistency of results, or clinical relevance of outcome measures. | See answer to previous question. | Although we now started using the formal grading system of evidence proposed by AHRQ to rate overall strength of evidence, we have not yet utilized an explicit framework for defining and identifying research gaps.
12 | Vanderbilt University EPC | Treatment of overactive bladder in women17 | Yes, although we would note that the terms “research gaps” and “research needs” had not entered the EPC language at the point this report was prepared and submitted for peer review. Overall our team has gravitated toward topics in which there are known and concerning gaps in the literature (e.g., management of uterine fibroids; fetal surgery), limitations in the study design and measurement methods of prior research (e.g., overactive bladder; definitions of chronic pelvic pain, fibroids in pregnancy), reservations about the quality of the technical implementation or documentation of research (e.g., new technologies for cervical cancer screening; secondary wound closure), a dearth of direct comparisons of treatments (e.g., management of preterm labor, episiotomy approach), modest use of patient reported outcome measures (cesarean on maternal request), little information about modifiers of treatment outcomes (traumatic brain injury), and a small pool of studies with direct applicability to the diversity of the clinical populations in which the diagnostic tool, device, or treatment is deployed (virtually universal). With few exceptions our work has included substantial components of non-randomized trial evidence so these challenges exist for all the reviews and are common dilemmas to be confronted in future research. From this experience we have developed a detailed framework for identifying research needs. We routinely consider the following information to characterize the status of current research and the needs for future research:; - Inventory and appraisal of strengths and weaknesses of operational definitions used at each phase of the research: inclusion and exclusion, exposures, outcomes, and key covariates/modifiers.; - Documentation of measurement methods used to implement operational definitions, with details such as documentation of validation and reliability of measures, for example commenting on the implications of defining gestational age at birth based on last menstrual period, birth certificate data, or ultrasound; or determining presence of a condition by medical record review, ICD-9, patient interview, or adjudicated decision trees.; - Semi-quantitative inventory of the prior study designs and the evidence or lack of evidence of the natural progression from lower levels of evidence through higher levels of evidence over time.; - Explicit documentation of gaps in availability of direct comparisons in comparable groups of common clinical care or diagnostic approaches.; - Applicability of existing research to the spectrum of individuals encountered in typical clinical practice and the possible influences of study design on understanding the likely achieved effects in real-world settings.; - Level of clinical uncertainty acknowledged by experts, providers, stakeholder organizations, and individuals.; - Degree to which the research provides insights into modifiers of treatment response, test performance characteristics, or device-related complications. (Generally we have key question focused on knowledge about modifiers. Given scant attention in most literature, this key question becomes an opportunity to discuss why it is an important gap within the key question results and discussion.); - Ethical frameworks that inform understanding of prior research and feasibility and design of future research.; - Potential influence of conflict of interest and regulatory requirements on the content of the literature and the nature of studies being conducted within a field. (See table 32 in OAB report for example of data to capture this.); Last as a working tool (not a component of the report) we consider a grid that includes the PICOTS elements along one axis in rows, and the elements outlined above along the other axis as column. This approach clearly identifies areas of concern as “vacancies” in the grid. Team members and an information scientist as well as the TEP are also involved in creating an inventory of ongoing trials/other important studies. We weigh this information (and often present it) in deciding what to emphasize or to tell readers to be looking for in future literature that may help close gaps. Within the EPC and the project teams we then discuss and ultimately establish consensus about the relative level of importance of particular elements to emphasize in the future research materials for a specific review. Of note, though at times encouraged to do so, we rarely describe specific studies that should be prioritized preferring to highlight methods that will provide cross- cutting improvements in the research, and a longer listing of gaps/needs without a sense of which is most important because different funders and research communities will likely have differential ability to focus on gaps/needs. | No, we consider most of our process internal ground work that helps assure a standardized process so that we don’t overlook any domains. Given desire for brief and readily consumed reports, we don’t find advantage to introducing more materials about method/process in the reports themselves (especially now with the development of future research needs documents as a separate product), but we would welcome some documentation of acceptable approaches that we could cite in order to refer interested readers to more detail and to be able to more briefly summarizes the approach used. INFORMATION INCLUDED IN THE ABSTRACTION TABLE; - Were research gaps defined? One described approach was to consider deficits that kept studies from achieving “good” quality ratings (p. 105). However, we concur we didn’t define what we meant by “gaps” -it wasn’t EPC jargon at the time the final draft was submitted – long lag to publication.; - Was there an explicit framework/ set of organizing principles (e.g., PICO, a diagram) used for the identification of research gaps/needs? Same comments – don’t think we were focused on the concept of gaps/needs in the way we are now at the time the report was prepared. Agree not methods described.; - Were future research gaps/ needs provided, and where were they found? Because gaps/needs is somewhat vague, I’d encourage us to keep thinking about specific needs for improvement in research methods that apply to the field as its own content. | We are still using the same core method, sometimes with embellishments where the gaps are more unique to the topic for instance a surgical device, diagnostic approach, or rare but devastating outcome. We are also currently leading a pilot project to explore ways of preparing the separate documents that will be focused on research gaps/needs. That project emphasizes using electronic processes to snow-ball ideas about gaps/needs and to then rank which have greatest attractiveness/urgency from the perspective of stakeholders. Would like to go on using a similar approach but time/effort/cost constraints will likely make this infeasible for the CERs themselves. Suspect these methods will be reserved to the future research needs documents when they are done as separate reports. Separate from EPC work we are exploring machine learning methods to glean future research needs from other documents more efficiently to explore whether this can be done more systematically.

Abbreviations: AHRQ=Agency for Healthcare Research and Quality, ARRA=American Recovery and Reinvestment Act, CER=comparative effectiveness review, DRI=dietary reference intake, HER2=human epidermal growth factor receptor 2, ICD=international classification of diseases, IOM=Institute of Medicine, IT=information technology, PICO=population, intervention, comparison, and outcomes, PICOS=population, intervention, comparison, outcomes, and settings, RAND=research and development, RCT=randomized controlled trial, RTI=Research Triangle Institute, TEP=technical expert panel, UNC=university of North Carolina.