# Appendix B Step 2: Review of Current Practices of Evidence-based Practice Centers (EPCs)—Data Abstraction Form for Audit of Evidence Reports

Sr. No. | Were Research Gaps/Needs Defined? | Was There a Description of How Research Gaps/Needs Were Identified? | Was There an Explicit Framework/Set of Organizing Principles (e.g., PICO, a Diagram) Used for the Identification of Research Gaps/Needs? | Were Future Research Gaps/Needs Provided in the Report? | Were Future Research Gaps/Needs Provided as a Part of the Discussion Section? | If Future Research Needs/Gaps Were ONLY Described in the Discussion and NOT in the Methods, Was There a Description (in the Results) of How They Were Identified? | How Were Research Gaps/Needs Presented? (INDICATE ALL WAYS PRESENTED)
1
2
3
4
5
6

Abbreviations: EPC=evidence-based practice center, PICO=population, intervention, comparison, and outcomes.