# Appendix A AHRQ’s Seven Questions About the Development, Prioritization, and Presentation of Research Needs

1. Define frameworks for determining research gaps conducted within a systematic review.
  - What are the various frameworks (concepts and organizing principles) used to determine the research gaps within a systematic review? (Research gaps are defined as missing evidence which limited the ability of reviewer to reach a conclusion for the given question.)
    ○ How often do the identified gaps extend beyond the reach of the original key questions?
  - Is there any evidence that one method for identifying research gaps is more valid than another?
  - Is there any evidence that one format for presenting research gaps is more useful than another?
2. Finding evidence on ongoing studies.
  - How can EPCs find information on currently ongoing studies?
    ○ What databases are available for searching?
    ○ Are there efficient methods for searching these databases?
    ○ What is the incremental benefit of additional grey literature searches?
3. Identify methods and processes for engaging stakeholders to define and prioritize research needs (i.e., decision-makers, researchers, funders).
  - What methods can be used to gather stakeholder input (individual calls, group calls/web-ex, in-person meetings etc.)?
    ○ What are the tradeoffs of each method?
    ○ Is one method is more useful for a certain type of question?
  - What methods can be to collate the stakeholder input (delphi, consensus, etc.)?
    ○ What are the tradeoffs of each method?
    ○ Is one method is more useful for a different purpose?
4. Define criteria for prioritizing research gaps to research needs.
  - What criteria do stakeholders use to prioritize research gaps?
    ○ Are they different for different stakeholders?
    ○ Are they different for different questions?
  - How can information be organized to facilitate stakeholder input?
5. Determine appropriate uses of modeling or VOI.
  - Describe different modeling or VOI methods that could be used for developing and prioritizing research gaps from systematic reviews.
    ○ What methods have been used?
    ○ What information is needed to such conduct modeling or VOI methods?
    ○ How can they be adapted to EPC purposes?
  - Is there any evidence that one method is more valid or useful than others?
6. Define an optimal format for presenting research needs.
  - What level of specificity is needed by various funders for a Research needs document to be useful?
    ○ Description of project design – i.e., study design, PICO questions, sample size
    ○ Background and justification of prioritized list.
  - How can research needs be categorized and presented?
    ○ Is there any evidence that one organization schema is preferred over another?
  - What are barriers to making a Research needs document useful to researchers and funders?
7. Assess the impact of developing Research Needs documents.
  - What is the current impact of the EPC program on currently funded studies?
  - How will development of Research Needs documents change the impact of the EPC program on funded studies?