# Acknowledgments

The Johns Hopkins University Evidence-based Practice Center (JHU EPC) thanks the technical experts, peer reviewers, and the AHRQ Task Order Officer (each listed below) for their contributions and help with this report. We also thank Laura Barnes, B.S., for her assistance in abstracting data from EPC evidence reports.