# Abbreviations

AAO-HNS: American Academy of Otolaryngology - Head and Neck Surgery Foundation
ACP: American College of Physicians
AETS: Agencia de Evaluación de Tecnologias Sanitarias
AETSA: Andalusian Agency for Health Technology Assessment
AETMIS: Agence d’évaluation des technologies et des modes d’intervention en santé (Québec Government Agency responsible for Health Services and Technology Assessment)
Age.na.s: The Agency for Regional Healthcare
AGREE: Appraisal of Guidelines Research and Evaluation
AHMAC: Australian Health Ministers Advisory Council
AHRQ: Agency for Healthcare Research and Quality
AHTA: Adelaide Health Technology Assessment
AHTAPol: Agency for Health Technology Assessment in Poland
ALT: Alanine Transaminase
ASERNIP-S: Australian Safety and Efficacy Register of New Interventional Procedures--Surgical
ASCO: American Society of Clinical Oncology
AST: Aspartate Transaminase
AUA: American Urological Association
AVALIA-T: Galician Agency for Health Technology Assessment
BMI: Body Mass Index
CADTH: Canadian Agency for Drugs and Technologies in Health
CAHIAQ: Catalan Agency for Health Information, Assessment and Quality
CARI: Caring for Australasians with Renal Impairment
CCE: Centre for Clinical Effectiveness
CCO: Cancer Care Ontario
CDE: Center for Drug Evaluation
CEA: Cost-Effectiveness Analysis
CEDIT: Comité d’Evaluation et de Diffusion des Innovations Technologiques
CENETEC: Centro Nacional de Excelencia Tecnológica en Salud
CER: Comparative Effectiveness Review
CIR: Center for International Rehabilitation
CMS: Center for Medicare and Medicaid Services
CNHTA: Committee for New Health Technology Assessment
COMPUS: Canadian Optimal Medication Prescribing and Utilization Service
CORE: Centralized Otolaryngology Research Efforts
CRD: Center for Reviews and Dissemination
CVZ: College voor Zorgverzekeringen
DACEHTA: Danish Centre for Evaluation and HTA
DAHTA@DIMDI: German Agency for HTA at the German Institute for Medical Documentation and Information
DECIT-CGATS: Secretaria de Ciência, Tecnologia e Insumos Estratégicos, Departamento de Ciência e Tecnologia
DRI: Dietary Reference Intake
DSEN: Drug Safety and Effectiveness Network
DSI: Danish Institute for Health Services Research
DUETS: Database of Uncertainties about the Effects of Treatments
EPC: Evidence-based Practice Center
ETESA: Department of Quality and Patient Safety of the Ministry Health of Chile
FDA: Food and Drug Administration
FinOHTA: Finnish Office for Health Technology Assessment
GDG: Guideline Development Group
G-I-N: Guidelines International Network
GmBH: Gesellschaft mit Beschränkter Haftung
GÖG: Gesundheit Österreich GmbH
GR: Gezondheidsraad
GRADE: Grading of Recommendations Assessment, Development and Evaluation
HAS: Haute Autorité de Santé
HER2: Human Epidermal growth factor Receptor 2
HIQA: Health Information and Quality Authority
HITAP: Health Intervention and Technology Assessment Program
HSAC: Health Services Assessment Collaboration
HTA: Health Technology Assessment
ICD: International Classification of Diseases
ICTAHC: Israel Center for Technology Assessment in Health Care
IECS: Institute for Clinical Effectiveness and Health Policy
IHE: Institute of Health Economics
INAHTA: International Network of Agencies for Health Technology Assessment
IOM: Institute of Medicine
IQWiG: Institut für Qualität und Wirtschaftlichkeit im Gesundheitswesen
IT: Information Technology
JBI: Joanna Briggs Institute
JHU EPC: Johns Hopkins University Evidence-based Practice Center
KCE: Belgian Health Care Knowledge Centre
KDOQI: Kidney Disease Outcomes Quality Initiative
LBI of HTA: Ludwig Boltzmann Institut für Health Technology Assessment
MaHTAS: Health Technology Assessment Section, Ministry of Health Malaysia
MAS: Medical Advisory Secretariat
MSAC: Medical Services Advisory Committee
MTU-SFOPH: Medical Technology Unit - Swiss Federal Office of Public Health
MUMM: Managed Uptake of Medical Methods
NBOCC: National Breast and Ovarian Cancer Centre
NETSCC, HTA: NIHR Coordinating Centre for Health Technology Assessment
NHSC: National Horizon Scanning Center
NICE: National Institute for Health and Clinical Excellence
NICU: Neonatal Intensive Care Unit
NIH: National Institutes of Health
NIHR: National Institute for Health Research
NKF: National Kidney Foundation
NOKC: Norwegian Knowledge Centre for the Health Services
NSAID: Non-Steroidal Anti-Inflammatory Drug
OSTEBA: Basque Office for Health Technology Assessment
PEBC: Program in Evidence-based Care
PICO: Population, Intervention, Comparison, and Outcomes
PICOS: Population, Intervention, Comparison, Outcomes, and Setting
QIS: Quality Improvement Scotland
RAB: Research Advisory Board
RAND: Research And Development
RCN: Royal College of Nursing
RCT: Randomized Controlled Trial
RFA: Request For Applications
RTI: Research Triangle Institute
SBU: The Swedish Council on Technology Assessment in Health Care
SCHIP: State Children’s Health Insurance Program
SIGN: Scottish International Guidelines Network
SSRI: Selective Serotonin Reuptake Inhibitor
STI: Sexually Transmitted Infection
TA: Technology Assessment
TEP: Technical Expert Panel
UETS: Unidad de Evaluación de Tecnologías Sanitarias
UK: United Kingdom
UNC: University of North Carolina
US: United States
USPSTF: United States Preventive Services Task Force
UVT: HTA Unit in A. Gemelli Teaching Hospital
VA: Veterans Affairs
VASPVT: State Health Care Accreditation Agency under the Ministry of Health of the Republic of Lithuania
VATAP: Veterans Affairs Technology Assessment Program
ZonMw: The Medical and Health Research Council of The Netherlands