# References

1 Agency for Healthcare Research and Quality. Future Research Needs. Methods Research Series.
2 Martin D, Singer P. (2003). A strategy to improve priority setting in health care institutions. Health Care Anal.
3 Institute of Medicine. (2008). Knowing what works in health care: a roadmap for the nation.
4 National Institutes of Health. (1997). Setting research priorities at the National Institutes of Health.
5 (2009). Federal Coordinating Council for Comparative Effectiveness Research Report to the President and the Congress.
6 Agency for Healthcare Research and Quality. What Is the Effective Health Care Program.
7 Whitlock E, Lopez S, Chang S, et al. (2010). AHRQ Series Paper 3: Identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the Effective Health Care Program. J Clin Epidemiol.
8 Agency for Healthcare Research and Quality. About Evidence-based Practice Centers (EPCs).
9 Robinson KA, Saldanha IJ, Mckoy NA. (2011). Frameworks for determining research gaps during systematic reviews, Methods Future Research Needs Report No. 2.
10 Viswanathan M, Nerz P, Dalberth B, et al. (2011). Assessing the Impact of AHRQ Evidence-based Practice Center Reports on Future Research, Methods Future Research Needs Report No. 7.
11 Agency for Healthcare Research and Quality. Future Research Needs Projects.
12 Agency for Healthcare Research and Quality. (2011). Framework for Considering Study Designs for Future Research Needs (FRN), Draft Methods Research Report.