# Prioritization

## EHC Topic Selection Criteria

The EHC Program has 5 domains with 18 criteria for the selection of topics for SRs/CERs.1,5 The five overarching domains are (Table 1): Appropriateness (three criteria), Importance (seven criteria), Duplication (one criterion), Feasibility (one criterion), and Potential Value (six criteria).1

Table 1 Effective Health Care Program topic selection criteria7

Appropriateness | 1 | Represents a health care drug, intervention, device, or technology available (or soon to be available) in the United States.
Appropriateness | 2 | Relevant to enrollees in programs specified in Section 1013 of the Medicare Modernization Act of 2003 (Medicare, Medicaid, Children’s Health Insurance Program [CHIP], other Federal health care programs).
Appropriateness | 3 | Represents one of the priority health conditions designated by the Department of Health and Human Services.
Importance | 1 | Represents a significant disease burden affecting a large proportion of the population or a priority population (e.g., children, elderly adults, low-income, rural/inner city, minorities, or other individuals with special health care or access issues).
Importance | 2 | Is of high public interest, affecting health care decision making, outcomes, or costs for a large proportion of the U.S. population or for a priority population in particular.
Importance | 3 | Was nominated/strongly supported by one or more stakeholder groups.
Importance | 4 | Represents important uncertainty for decisionmakers.
Importance | 5 | Incorporates issues around both clinical benefits and potential clinical harms.
Importance | 6 | Represents important variation in clinical care or controversy in what constitutes appropriate clinical care.
Importance | 7 | Represents high costs due to common use, high unit costs, or high associated costs to consumers, patients, health care systems, or payers.
Desirability of new research / duplication | 1 | Potential for redundancy (i.e., whether a proposed topic is already covered by an available or soon-to-be available high-quality systematic review by AHRQ or others).
Feasibility | 1 | Effectively utilizes existing research and knowledge by considering:
Feasibility | 1 | Adequacy (type and volume) of research for conducting a systematic review.
Feasibility | 1 | Newly available evidence (particularly for updates or new technologies).
Potential value | 1 | Potential for significant health impact:
Potential value | | To improve health outcomes.
Potential value | | To reduce significant variation in clinical practices known to be related to quality of care.
Potential value | | To reduce unnecessary burden on those with health care problems.
Potential value | 2 | Potential for significant economic impact:
Potential value | | To reduce unnecessary or excessive costs.
Potential value | 3 | Potential for change:
Potential value | | Proposed topic exists within a clinical, consumer, or policymaking context that is amenable to evidence-based change.
Potential value | | A product from the EHC program could be an appropriate vehicle for change.
Potential value | 4 | Potential risk from inaction:
Potential value | | Unintended harms from lack of prioritization of a nominated topic.
Potential value | 5 | Addresses inequities, vulnerable populations (including issues for patient subgroups).
Potential value | 6 | Addresses a topic that has clear implications for resolving important dilemmas in health and health care decisions made by one or more stakeholder groups.

Abbreviations: AHRQ = Agency for Healthcare Research and Quality; EHC = Effective Health Care

FRNs, by definition, derive from existing CERs and those CERs, in order to be conducted under the EHC Program, should have already fulfilled the selection six criteria listed in Table 2. As a result, one does not necessarily need to revisit all of these criteria again when prioritizing FRNs.5 Of the aforementioned topic selection criteria, the three criteria of Appropriateness and the first three criteria of Importance are the default criteria; for clarity, these criteria could potentially be listed in a footnote with the FRN prioritization (Table 2).

Table 2 Default criteria—always met prior to future research needs proposals^*^

Represents a health care drug, intervention, device, or technology available (or soon to be available) in the United States.
Relevant to enrollees in programs specified in Section 1013 of the Medicare Modernization Act of 2003 (Medicare, Medicaid, Children’s Health Insurance Program [CHIP], other Federal health care programs).
Represents one of the priority health conditions designated by the U.S. Department of Health and Human Services.
Represents a significant disease burden affecting a large proportion of the population or a priority population (e.g., children, elderly adults, low-income, rural/inner city, minorities, or other individuals with special health care or access issues).
Is of high public interest, affecting health care decision making, outcomes, or costs for a large proportion of the U.S. population or for a priority population in particular.
Was nominated/strongly supported by one or more stakeholder groups.

Abbreviations: CER = comparative effectiveness review; SR=systematic review

* Appropriateness and Importance criteria included by default, in consideration of the fact that Future Research recommendations are made in the context of an EHC Systematic Review or Comparative Effectiveness Review, and all commissioned topics have met these criteria prior to selection for SR/CER and do not have be rechecked for FRN prioritization

Of the remaining three EHC topic selection criteria (Desirability of New Research/Duplication, Feasibility, and Potential Value), there is a natural division in the appropriate stage for application of criteria and expertise needed to apply the criteria. The criterion of Feasibility is appropriate only when considering a specific research design and best applied by persons with expertise in conducting primary research. On the contrary, stakeholders who will be using the research to make decisions need to consider whether suggested research would be helpful (have Potential Value), especially in relation to ongoing or already conducted research (Desirability of new research/duplication). Therefore, when prioritizing future research needs, the process may be completed sequentially; first working with stakeholders to consider potential value and desirability, and then considering study design and feasibility as the subsequent step.

## Prioritization of Future Research Needs

After identifying the research gaps from a CER/SR, the EPC will work with stakeholders to identify the research that would fill those gaps, and then prioritize the research areas that are the most important. The EPC will identify and actively engage the important partners with a stake in conducting, funding, or using future research. Gathering meaningful input requires a careful selection of representatives as well as establishing a fair process for considering their input. This is often a multistep process. Initial engagement of stakeholders begins with orientation to the topic, goals, process, and expectations (Figure 1, bullet 2). EPCs have frequently, at this early stage, also solicited suggestions for research gaps from stakeholders.

Discussing future research needs for the clinical management of a condition will often require specification of the PICO elements (People/Population/Subpopulation/Patients with the condition, Intervention [Exposure, Test], Comparators, and Outcomes, Figure 1, bullet 4). A description of the population or subpopulation (P) to be studied should be stated. The proposed intervention and proposed comparator(s), if any, should be itemized (I,C); the comparator could be a placebo or a head to head comparison with another active intervention. The proposed primary and secondary outcome measures, including surrogate measures and process measures should be itemized (O). Some of the research needs may be methodologic, and the PICO model will not apply. Methods research needs could be prioritized separately from content research needs.

The EPC will engage the stakeholders to consider which of these future research topic areas have the highest potential value (Figure 1, bullet 5). In order to inform the ranking process, we propose six potential value criteria (Table 3). The components of potential value criteria include the importance of the condition, the importance of the evidence gap between what we know and what we need to know (degree of uncertainty), and the known degree of inappropriate variability in the management of the condition or controversy about what constitutes appropriate clinical care. The evidence gap may involve knowledge, or knowledge translation, or implementation, or a combination. EPCs have found that it often required at least two rounds of interaction with stakeholders to achieve prioritization of specific research questions. The first step may be to identify those areas of gaps that have been or will be covered by ongoing or existing research. In this step (Figure 1, bullet 3), the EPC will conduct a targeted scan of ongoing research. In the first phase of interaction with stakeholders, the lists of research needs are refined, with greater specificity and a preliminary round of prioritization may occur. In the second phase of interaction with stakeholders, final prioritization of the future research needs will be completed.

Table 3 PiCMe potential value criteria

PiCMe Criteria: EHC Criteria, Modified for Future Research, Supplemented With Additional Criteria
| Potential value criteria (for significant health impact): addressing evidence gap (knowledge, translation, implementation)
V1 | Potential for new knowledge (Research would not be redundant: Strength of evidence is not high for specific outcome [confidence in the estimate of effect is moderate or low]; Question not sufficiently researched, including completed and in-process research; Utility of available evidence limited by changes in practice, e.g., disease detection or evolution in technology); more evidence needed about values and preferences influencing balance of benefits and harms/risks.
V2 | Potential for significant health impact on the current and projected health status of people with respect to burden of the disease and health outcomes: mortality, morbidity, and quality of life.
V3 | Potential to reduce important inappropriate (or unexplained) variation in clinical practices known to relate to quality of care. Potential to resolve controversy or dilemmas in what constitutes appropriate health care. Potential to improve decisionmaking for patient or provider, by decreasing uncertainty.
V4 | Potential for significant economic impact related to the use of health service resources. Many healthcare resource use factors may be expressed as cost. Potential to reduce unnecessary or excessive costs; to reduce high costs due to high volume use; to reduce high costs due to high unit cost or aggregate cost. Costs may impact consumers, patients, caregivers, employers, health care systems, or payers.
V5 | Potential risk from inaction: Unintended harms from lack of prioritization of proposed research; opportunity cost of inaction; potential to allow assessment of ethical, legal, social issues pertaining to the condition.
V6 | Addresses inequities, vulnerable, diverse populations (including issues for patient subgroups); potential to reduce health inequities; potential to allow assessment of ethical, legal, social issues pertaining to the condition.

Abbreviations: EHC = Effective Health Care; PiCMe = Prioritization Criteria Methods

After completing the potential value prioritization process, the next step would be an effort to delineate study design and other parameters of the envisioned research (Figure 1, bullet 6).

Discussing the potential value of a future research need will sometimes be supported by specification of the PICOTS elements, and by presentation of the current strength of evidence (SoE) for the specific outcome of the PICOTS, based upon the current best evidence summarized in the CER/SR. The current strength of evidence could be used as a factor in the potential value prioritization; if the current SoE is low, higher value might be associated with new knowledge than if the current SoE is moderate. The PICO may be important in a situation where there is high SoE for one population group, but low or insufficient for another group; the PICO specificity would clarify that the prioritization was for the future research need for that specific population.

Different techniques may be used to support the stakeholder prioritization, using the criteria. One approach is to use multivoting or other ranking technique to shorten the initial list of FRNs, and then using a numeric scoring of each criterion for each FRN proposal to arrive at a prioritized rank order. Another approach is to use a numeric scoring of each criterion for each FRN proposal as an initial step, and then shorten the list to the high-scoring group, followed by a voting or multi-voting technique to arrive at a prioritized rank order. Likert scale numeric selection for each criterion for each FRN proposal could also be used, as an alternative to multi-voting. Regardless of the approach taken, it should be identified a priori in a project protocol and reported clearly and transparently in the final product.

It is not the intent of this paper to assert that each criterion is equal in value to each other criterion. For any given clinical topic, the relative value of the criteria may differ from another clinical topic. We suggest that choosing not to apply a weighted value to each criterion effectively means a de facto equal value of one for each criterion. Stakeholders may assign a numeric value (weight) to each of the six criteria, so that this value may be multiplied by the prioritization assessment to provide a balance of criteria that reflects the relative values. If stakeholders do not explicitly assign a weight to each criteria, or there is not agreement among stakeholders, the EPC may ask the stakeholders to be explicit about which criteria was most important when they selected their top priority research needs, and document this.

The approaches described here may be adapted based on decisions by the EPC and the stakeholders; including but not restricted to the criteria themselves; the techniques for applying the criteria, and the weight or value of each criterion. More practical testing is likely to be informative.

## Criteria for Considering Study Designs

Beyond identifying future research needs of high importance to decisionmakers, it is also important to work with stakeholders to understand the feasibility of conducting new research that can answer the question being asked. It is important to engage a broad range of researchers experienced in various methodology types to identify what studies could possibly be conducted to help answer the question. The studies needed to answer many questions may not be feasible due to issues such as study design, capacity, ethical issues, duration, or rarity of disease.

Once the stakeholders have identified the questions that need to be answered to make decisions, the next step is to consider what study design is both feasible and likely to answer the questions in a valid manner. Another methods paper focuses on the steps for considering the study designs to address research needs.12