# Methods

We reviewed the prioritization criteria that the EPCs used in their pilot projects11 and the EHC program topic selection criteria.7 We modified the EHC topic selection criteria by adjusting for the differences between planning a systematic review of existing evidence and proposing future research to address gaps in the existing evidence. We mapped the prioritization criteria developed by the eight EPCs that conducted pilot FRN projects into the preexisting EHC topic selection criteria, acknowledging repetition and adding wording that enhanced the criteria description. After modification, the remaining criteria were divided into two prioritization steps as appropriate to the process of identifying FRNs and suggesting specific study designs. These criteria and steps were shared with EPCs that continue to conduct FRN projects and are reported below as suggested practices.