# Peer Reviewers

Muhammad Ansari M.B.B.S., M.Med.Sc., M.Phil.

Associate Director,

University of Ottawa Evidence-based Practice Center

Centre for Practice-Changing Research

Ottawa Hospital Research Institute

Timothy S. Carey, M.D., M.P.H.

Co-Director, RTI-UNC Evidence-based Practice Center

Kenan Professor of Medicine

Director, Cecil G. Sheps Center for Health Services Research

Deputy Director, UNC Program on Health Outcomes

University of North Carolina at Chapel Hill

Jeanne-Marie Guise M.D., M.P.H.

Oregon Health & Science University

Robert L. Kane, M.D.

Co-Director, University of Minnesota Evidence-based Practice Center

Minnesota Chair in Long-Term Care and Aging

University of Minnesota School of Public Health