# Conclusions

CERs identify important gaps in evidence; these can be used to inform future research needs. FRNs can be used by researchers and funders advance the knowledge base. Integral to this process is having explicit criteria for prioritizing the FRNs. This paper describes a methodology for prioritizing the FRN recommendations. The proposed methodology used the foundation of existing EHC topic selection criteria and adapted them to be fit for purpose for the stakeholders with an interest in identifying prioritizing future research needs. This paper particularly focuses on the Potential Value criteria used when working with stakeholders to prioritize the FRN proposals derived from a CER/SR.