# Background

Research prioritization is one of the key nodal points in the research policy planning cycle, which encompasses research planning, research priority setting, strategies and implementation of research priorities, research utilization, research monitoring and evaluation (part of the research information system), and overall research policy management. In recognition of the resource, human, and financial costs of conducting research, the changing determinants and pattern of diseases or conditions and their effect on the population at large, and the evolving body of evidence, prioritization of future research needs must be responsive and dynamic and should be periodically reviewed and updated.

The process of making decisions about health-related priorities is complex and context-dependent and involves social processes. Therefore, priority-setting processes should be guided by ethical principles, including careful attention to conflicts of interest.1,2 Documentation of the process leading to a particular proposal being selected should be explicit and transparent.1,3 Other key principles for the priority-setting process include flexibility, adaptability to dynamic advances, and accountability.1,3

Research prioritization takes place within the framework of the national health policies and national health research policies. For example, although federally funded research priorities in the United States are largely investigator initiated,4 in making funding decisions, the National Institutes of Health and other Federal agencies consider the impact of potential research in light of burden needs of society, existing scientific opportunities, the quality of individual research proposals, the experience of the applicant, and the ability to sustain research through adequate staffing and infrastructure.4 The prioritization process should be well documented for future reference, particularly where judgments and opinions are integral. All of the criteria used for research prioritization should be clear and also independent of each other.

Comparative effectiveness research is the conduct and synthesis of systematic research comparing different interventions and strategies to prevent, diagnose, treat, and monitor health conditions. The purpose of this research is to inform patients, providers, and decisionmakers, while responding to their expressed needs about which interventions are most effective for which patients under specific circumstances. The Federal Coordinating Council (FCC) for Comparative Effectiveness Research defined comparative effectiveness research and draft prioritization criteria for making research selections.5 The definition and criteria were a guide to the Federal use of the funding appropriated for comparative effectiveness research in FY 2009 and FY 2010 in the American Recovery and Reinvestment Act.

The FCC established:

- Threshold minimal criteria (i.e., must meet these to be considered) for the prioritization criteria for comparative effectiveness research:
  ○ Included within statutory limits of Recovery Act and FCC definition of comparative effectiveness research
  ○ Responsiveness to expressed needs and preferences of patients, clinicians, and other stakeholders, including community engagement in research
  ○ Feasibility of research topic (including time necessary for research)
- Prioritization criteria:
  ○ Potential impact (based on prevalence of condition, burden of disease, variability in outcomes, and costs of care)
  ○ Potential to evaluate comparative effectiveness in diverse populations and patient subpopulations
  ○ Uncertainty within the clinical and public health communities regarding management decisions
  ○ Addresses need or gap unlikely to be addressed through other funding mechanisms
  ○ Potential for multiplicative effect (e.g., lays foundation for future comparative effectiveness research or generates additional investment outside government)

The Agency for Healthcare Research and Quality (AHRQ) through its Effective Health Care (EHC) Program funds individual researchers, research centers, and academic organizations to conduct effectiveness and comparative effectiveness research for clinicians, consumers, and policymakers.6 AHRQ is the lead Federal agency charged with improving the quality, safety, efficiency, and effectiveness of health care for all Americans. The EHC Program has carefully considered the range of principles and criteria and established a process for selecting research topics within the EHC program, using 5 domains with 18 criteria.7 The EHC Program partners with networks of researchers and clinical teams across North America, using input from stakeholders throughout the process of comparative effectiveness research, translation, dissemination, and implementation of research findings.6

As one of the components of the EHC Program, the Evidence-based Practice Centers (EPCs) perform systematic reviews of existing evidence.8 Comparative effectiveness reviews (CER) and systematic reviews (SR) are intended to review and present the relevant evidence to inform real-world health care decisions for patients, providers, and policymakers. Beyond synthesizing the evidence, CERs identify gaps in evidence that may have limited the ability to answer the research topics.1 In most situations, there will be many more research gaps than can be reasonably narrowed in the near future, and many more future research needs proposals than can be reasonably undertaken. Therefore, prioritization of the proposals will be helpful, and it is desirable that the prioritization process be transparent and as consistent as possible among groups. Therefore, as part of an effort begun in 2010, AHRQ supported EPCs to work with various stakeholders to further develop and prioritize the future research needed by decisionmakers, including primary research and methods research (Figure 1).9,10 These future research needs (FRN) projects are intended to be used by researchers and funders of research to help improve the body of evidence as needed for decisionmakers. There was no previously established methodology for FRN projects, and the EPCs have been utilizing various methods for identifying and prioritizing evidence needs.11 One of the steps in this process is the definition of specific prioritization criteria, and in these pilot projects, EPCs and stakeholders used various implicit or explicit criteria.

Figure 1 Flowchart of future research needs process

Abbreviations: CER = comparative effectiveness review; EPC = Evidence-based Practice Center; FRN = future research needs

* May include identification of additional evidence gaps.

† Reduction through topic consolidation, preliminary prioritization, and consideration of ongoing research (duplication criteria).

‡ Evidence gaps that address specific methods issues would not use PICOTS framework

¥ May require iterative steps

Figure 1: Proposed Steps in Prioritizing Future Research Needs. This figure outlines the process for prioritizing research gaps into future research needs. The steps in the process include: 1. Publication of the draft systematic review with the Evidence-based Practice Center (EPC)-determined evidence gaps 2. Orientation of stakeholders to comparative effectiveness review question, future research needs process, prioritization criteria 3. Identification of the evidence gaps with stakeholders (variable) 4. Priority ranking of the evidence gaps consideration of ongoing research (duplication criteria) 5. Transformation of evidence gaps into research questions with Population, Intervention, Comparator(s), Outcomes, Timing, Setting (PICOTS) framework 6. Re-ranking of priorities by stakeholders (potential value criteria) 7. EPC consideration of study design considerations (including likelihood and feasibility criteria) 8. Publication of a future research needs document.

The objective of this methods paper is to propose when, how, and which specific criteria can be explicitly considered when identifying the highest priority research needs.