# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project:

Melissa McPheeters, Ph.D., M.P.H.

Co-Director, Vanderbilt Evidence-based Practice Center