# References

1 The World Health Organization. International Clinical Trials Registry Platform.
2 (2009). Higgins JPTGS, editor. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.2.
3 United States National Library of Medicine NIoH. FAQ: ClinicalTrials.gov—What is the FDAMA?.
4 International collaborative group on clinical trial registries. (1993). Position paper and consensus recommendations on clinical trial registries. Ad Hoc Working Party of the International Collaborative Group on Clinical Trials Registries. Clinical Trials & Meta-Analysis.
5 Kuehn B. (2009). Clinical Trials Registry Expands. JAMA.
6 O’Kelly M, Julious S, Pyke S, et al. Making available information from studies sponsored by the pharmaceutical industry: some current practices. Pharmaceutical Statistics.
7 De Angelis C, Drazen JM, Frizelle FA, et al. (2004). Clinical trial registration: a statement from the International Committee of Medical Journal Editors. Annals of Internal Medicine.
8 Laine C, Horton R, DeAngelis CD, et al. (2007). Clinical trial registration: Looking back and moving ahead. Annals of Internal Medicine.
9 Moja LP, Moschetti I, Nurbhai M, et al. (2009). Compliance of clinical trial registries with the World Health Organization minimum data set: a survey. Trials [Electronic Resource].
10 Collier R. (2009). Clinical trial registries becoming a reality, but long-term effects remain uncertain. Canadian Medical Association Journal.
11 Drazen JM, Zarin DA. (2007). Salvation by registration. New England Journal of Medicine.
12 Zarin DA, Tse T, Ide NC. (2005). Trial Registration at ClinicalTrials.gov between May and October 2005. New England Journal of Medicine.
13 Dwan K, Altman D, Arnaiz J, et al. (2008). Systematic review of the empirical evidence of study publication bias and outcome reporting bias. PLoS ONE [Electronic Resource].
14 Ramsey S, Scoggins J. (2008). Commentary: practicing on the tip of an information iceberg? Evidence of underpublication of registered clinical trials in oncology. Oncologist.
15 Rasmussen N, Lee K, Bero L. (2009). Association of trial registration with the results and conclusions of published trials of new oncology drugs. Trials [Electronic Resource].
16 Ross JS, Mulvey GK, Hines EM, et al. (2009). Trial publication after registration in ClinicalTrials.Gov: a cross-sectional analysis. PLoS Medicine/Public Library of Science.
17 Song F, Parekh-Bhurke S, Hooper L, et al. (2009). Extent of publication bias in different categories of research cohorts: a meta-analysis of empirical studies. BMC Medical Research Methodology.
18 Mathieu S, Boutron I, Moher D, et al. (2009). Comparison of registered and published primary outcomes in randomized controlled trials.[Erratum appears in JAMA 2009 Oct 14;302(14):1532]. JAMA.
19 Easterbrook P. (1992). Directory of registries of clinical trials. Statistics in Medicine.
20 Damle A, Lurie P, Wolfe S. A Policy Study of Clinical Trial Registries and Results Databases.
21 WHO. International Clinical Trials Registry Platform Search Portal.
22 IFPMA. IFPMA Clinical Trials Portal.
23 clinicaltrials.gov. ClinicalTrials.gov.
24 ISCTRN. ISRTCN.
25 Gold JL, Studdert DM. (2005). Clinical trials registries: a reform that is past due. Journal of Law, Medicine & Ethics.
26 University of Michigan UMClinicalStudies.org.
27 Internet Stroke Center at Washington University. Stroke Trials Registry.
28 Trials CC. metaRegister of Controlled Trials.
29 PhRMA. Clinicalstudyresults.org.
30 Zarin DA, Tse T. (2008). Tracking health services research studies. JAMA.
31 Surveymonkey.com. SurveyMonkey.
32 Santaguida P. (2004). Pharmacological treatment of dementia.
33 Sharma M. (2005). Acute stroke: evaluation and treatment.
34 Piper M, Seidenfeld J, Aronson N. (2004). Islet transplantation in patients with Type I diabetes mellitus.
35 Beach M, Cooper L, Robinson K, et al. (2005). Strategies for improving minority healthcare quality.