# Executive Summary

## Background

Comparative effectiveness reviews synthesize evidence to inform questions about healthcare topics, but the evidence is not always sufficient to completely answer those questions. Therefore systematic reviews and specifically Evidence-based Practice Center (EPC) reports may identify research gaps and make recommendations for future research to address these unanswered questions. One useful adjunct to these recommendations is an analysis of the research that is currently in the pipeline. This additional information can be used to prioritize the research gaps in the report. Identified research gaps on topics for which several large studies are underway can be described as a lower priority future research need. Identified research gaps on topics with few studies underway may rise as priorities for future research. Prioritizing the research gaps this way can also guide funding agencies in decisions about which topics may need additional research funding. The information provided about ongoing studies can provide indications about when to update reviews.

This project assessed this potential adjunct of reviewing ongoing studies when addressing future research needs through two aims. First sources of information that can be used to identify ongoing studies relevant to the research gaps were analyzed. Second, we evaluated the value that could be added by utilizing these sources in refining the research recommendation section of an EPC report. The second aim was to determine if there are characteristics of ongoing studies that can be used to predict which studies will be completed as planned and published in a timely manner. We addressed the following key questions during the completion of this project:

1. What sources of information are available to identify ongoing studies?
  a. Is the metadata provided, and are indexing and search capabilities in these sources easy to use and understand in identifying studies pertaining to specific research questions?
  b. What are the strengths and weaknesses of these sources?
2. For research questions pertaining to research gaps identified in past EPC reports, how often do these information sources list relevant ongoing studies?
  a. Are there study characteristics that can be used to predict which studies will be completed as planned and published in a timely manner (sponsorship, topic area, etc.)?
  b. Can study characteristics predict which studies will be completed as planned and published in a timely manner (sponsorship, topic area, etc.)?

## Methods

The aims of this project were investigated primarily qualitatively in several steps. First, we reviewed literature to develop the background on this topic. Second, we solicited expert opinion from EPC librarians to generate a list of sources (i.e., trial registries, funded research databases, other grey literature sources) useful in identifying ongoing studies. Librarians were also queried regarding the strategies and techniques they use when searching for ongoing studies.

For the next phase of this project, we identified all AHRQ EPC reports published in 2004–2005. We evaluated whether the completed and published EPC reports identified research gaps. We then searched for studies ongoing at the time the reports were published. From this group of 49 EPC reports, 4 were analyzed in more detail. The four were selected because they represented topics with significant research activity and they represented different areas of comparative effectiveness research (i.e., pharmacological or surgical interventions, complex disease management, or health services research) and a variety of topics. We searched topically for ongoing studies that were relevant for each of the four selected reports in the identified databases. We pragmatically evaluated the databases using the following criteria:

- How can the database be searched (i.e., topic, study design)?
- Can information about studies be downloaded for efficient analysis?
- Do databases provide study completion dates and links to publications in peer reviewed journals?
- Does the database provide sufficient information about the study?

We assessed relevance of each ongoing study according to EPC report criteria for study inclusion. Relevance was subjectively determined on topic by one study author. We evaluated completeness of the study according to recruitment status. We evaluated publication status in peer reviewed journals and a presentation of the results in scientific meetings. Sponsorship, topic (cancer, heart disease, etc.) and/or context area (i.e., devices, drugs, procedures, diagnostic methods) were qualitatively assessed to suggest factors that might predict relevance and utility of the completed study and associated end-products in meeting the future research needs identified in the EPC report.

## Results

Several online information sources are available to search for ongoing studies. Librarians typically search a few of these sources to identify ongoing studies (Executive Summary Table 1). The single most commonly used source for identifying ongoing clinical trials appears to be ClinicalTrials.gov. Beyond ClinicalTrials.gov, additional international trials are sometimes identified through the International Clinical Trials Registry Platform (ICTRP) which is a search portal maintained by the World Health Organization (WHO) that aggregates information from several registries. Several sources that maintain databases of funded research are also available to search for ongoing studies. These are especially useful when searching for studies that are not clinical trials. The two sources most frequently utilized to search for funded research included the National Library of Medicine’s Health Service Research Projects in Progress (HSRProj) and the National Institutes of Health Research Portfolio Online Reporting Tools Expenditures and Results (RePORTER). Questionnaire respondents found HSRProj to have a more pleasing interface than the RePORTER. The RePORTER seemed to be more comprehensive as it includes all National Institutes of Health (NIH) funded research where HSRProj focuses on health services research topics. Grey literature sources were also important to librarians searching for ongoing studies. Other grey literature sources mentioned included Food and Drug Administration databases, topic-specific conference proceedings, and Web sites recommended by content experts.

Table A Data sources used to find ongoing studies

Data Source | Always (N) | Always (%) | Sometimes (n) | Sometimes (%) | Never (n) | Never (%)
Portals
ICTRP | 1 | 11.0% | 6 | 67.0% | 2 | 22.0%
IFPMA | 0 | 0% | 0 | 0% | 8 | 100%
International and National Registries
Clinicaltrials.gov | 7 | 87.5% | 1 | 12.5% | 0 | 0%
ISCTRN | 2 | 25.0% | 1 | 12.5% | 5 | 62.5%
Other government | 0 | 0% | 4 | 50.0% | 4 | 50.0%
Industry
Specific pharmaceutical company | 1 | 12.5% | 4 | 50.0% | 3 | 37.5%
PhRMA clinicalstudyresults.org | 1 | 12.5% | 0 | 0% | 7 | 87.5%
Specialty
Academic | 0 | 0% | 2 | 25.0% | 6 | 75%
Subject specific | 1 | 12.5% | 3 | 37.5% | 4 | 50.0%
Databases of Funded Research
HSRProj | 2 | 25.0% | 2 | 25.0% | 4 | 50.0%
RePORT | 3 | 37.5% | 0 | 0% | 5 | 62.5%
AHRQ GOLD | 1 | 12.5% | 1 | 12.5% | 6 | 75%
Specific Foundations | 0 | 0% | 2 | 28.6% | 5 | 71.4%

The majority of the EPC reports published in 2004–2005 included future research recommendations. However, reports did not address ongoing studies when making research recommendations. The number of ongoing studies at the time when the reports were completed varied across topics without visible patterns. The following four EPC titles were selected for more detailed analysis of related ongoing studies:

- Quality of Care in Minority Health
- Islet Cell Transplantation
- Diagnosis and treatment for Acute Stroke
- Pharmacological Treatments for Dementia

The next phase of the project included following the ongoing studies relevant to these four reports forward through the next 5 to 6 years. Several observations were made during this process. Trial registries and funded research databases did not provide complete information about all ongoing studies. One registry, ClinicalTrials.gov, and two funded research databases, NIH RePORTER and AHRQ GOLD, allowed for comparatively efficient searching by topic or study design. Retrieved data can be downloaded from ClinicalTrials.gov and most of the funded research databases we evaluated. Trial registries typically provided sponsor name but not exact grant numbers. Funded research databases do not appear to provide study registration status. In general, trial registries and funded research databases did not appear to link to each other. ClinicalTrials.gov complies with the WHO minimum dataset requirements providing detailed study design, recruitment activities, ethics review of research, target sample size, subject inclusion criteria, and primary and secondary outcomes.1 ClinicalTrials.gov included links to publications in Medline. Two funded research databases are linked to all publications in which the project was mentioned, but all are not necessarily results of the exact study that was funded. ClinicalTrials.gov and ClinicalStudyResults.org allow posting of study results. Trial registries do not have information about all funded studies. Only the NIH REPORTER has a complete list of all grants sponsored by NIH.

The precision of searches for ongoing studies in different sources varied across databases. Generally, for the searches we performed, ClinicalTrials.gov provided the most precise search results. Information about study status (i.e., recruiting, completed, terminated) was available only in trials registries and not in funded research databases. Publication rates varied among our four topics. Publications appeared more common among the ongoing studies we identified in the NIH RePORTER than in ClinicalTrials.gov, consistent with previous results concerning sponsorship and publication. In the four studies we investigated, drug studies seemed to be published less often than other interventions. The studies with posted results tended to be published more often than those without posted results. Publication rates appeared to differ across sponsorship category with government sponsored research being published more frequently than industry sponsored research in three of our four topics.

## Conclusions

In general, it seems there is little certainty that ongoing studies will be completed in a manner that contributes useful evidence. Searching for ongoing studies may not warrant a significant investment of resources. However, information about ongoing studies is useful in prioritizing the identified research gaps. Therefore, searching these sources as efficiently as possible is important and useful to refining the future research needs section of EPC reports. To do this, the highest priority should be to search those sources that are likely to provide the largest yield and provide the most useful data on the ongoing studies in a useable way.

Based on our qualitative assessment of identifying ongoing studies, we recommend searching at least two sources for clinical studies, ClinicalTrials.gov and the ICTRP. These two sources should provide a fairly complete list of registered studies, they are relatively easy to use, and data on selected studies can be downloaded from ClinicalTrials.gov. Searching for nonclinical ongoing studies should be conducted in a more targeted manner. The NIH RePORTER provides complete information about NIH funded studies but few details regarding study design and protocol. HSRProj and AHRQ GOLD also provided information on studies and were considered excellent sources for finding ongoing studies that would not necessarily be in a clinical trials registry (observational studies or health services research topics). Supplementing these sources with targeted grey literature searching may uncover a portion of ongoing studies.

Completeness rates were high for all topics. Publication rates were higher but less accurate among studies identified in the NIH RePORTER. Nearly half of the registered studies were not published. Sponsor factors were the most obviously associated with publication.

It is also important that caveats regarding the potential of ongoing studies to fill the research gap be addressed when listing ongoing studies. The extent of protocol changes and low publication rates among registered studies indicates that identified ongoing studies should be watched for completion, publication, and posting of results (as is now required by law) and not automatically relied upon to fill a research gap.