# 5 Conclusion

Searching for ongoing studies in relevant information sources and screening those results for relevance to an identified research gap is a time consuming process. Because it appears that there is little certainty that identified ongoing studies will be conducted and completed in a manner that contributes useful evidence, searching for ongoing studies may not warrant a significant investment of resources. However, the identification of ongoing studies is valuable in helping to prioritize identified research gaps. Research gaps for which there exist many large federally funded studies may not be as important as research gaps where there are few industry sponsored studies. This information is also valuable in determining timelines for updating reports and provides a listing of studies that should be watched by topic stakeholders. Searching for ongoing studies as efficiently as possible is important. To do this, the highest priority should be to first search those sources that are likely to provide the largest yield and provide a sufficient amount of data on ongoing studies in the most useable way. For this reason, we recommend first using ClinicalTrials.gov and supplementing that data identified and downloaded from this source with a search of the ICTRP.

Efficiently searching for ongoing studies regarding health services research topics or for observational studies is not as straightforward. However, a strategy of selecting one or two general sources of funded research (NIH RePORTER, HSRProj, AHRQ GOLD) supplemented by topic-specific grey literature searches is likely the best method of finding ongoing studies for these topics. Guidance in identifying subject-specific sources should be obtained by reviewing websites of sponsors of similar funded research or via sources identified by content experts affiliated with the project.

And finally, when addressing the ongoing studies relevant to EPC reports it is also important that caveats regarding the potential of these ongoing studies to fill the research gap be addressed. The extent of protocol changes and low publication rates for registered studies indicates that ongoing studies should be watched for completion and publication or results posted to the registry (as is now required by law) and not relied upon to fill a research gap. We have even less information about which to base reliance on ongoing health services research or observational studies to eventually fill research gaps. Therefore, staying abreast of research regarding ongoing studies is another important activity to EPC practice.