# 4 Discussion

The objective of this methods project was to assess the sources and strategies for finding ongoing studies relevant to the identified research gaps in EPC reports. We identified several sources that can be useful in identifying ongoing studies. For finding ongoing clinical trials, ClinicalTrials.gov offers a fairly comprehensive registry of clinical trials, is relatively easy to use, and provides sufficient data about trials from which to estimate study quality. Results of a study by Moja et al. (2009) support the EPC staff assessments that ClinicalTrials.gov provides a sufficient amount of data to adequately describe the ongoing research.9 Moja et al. found that ClinicalTrials.gov was one of only three registries that complied with the WHO minimum data set for trial reporting. Clearly, this resource is the most valuable to finding ongoing clinical trials. One downside is that solely using ClinicalTrials.gov could miss important trials of interventions that are not marketed in the United States. Fortunately, a convenient resource exists to perform federated searches of multiple clinical trials registries—the ICTRP. Because the ICTRP is frequently updated and can be searched to find trials in several countries, it is a very valuable source for finding ongoing clinical studies. Yield of additional registered clinical trials beyond those found in these two trials sources is likely to be low.

Searching ClinicalTrials.gov and the ICTRP is likely valuable to all EPC reports on clinical interventions. There may be special circumstances where utilizing other sources may be warranted. For instance, it may be worthwhile to search pharmaceutical company registries when studying a new drug developed by certain manufacturers. In this case, researchers may want to supplement the above sources by adding searches in industry registries. Leads to appropriate grey literature sources are best identified with assistance from content experts representing the full range of stakeholders to the topic.

Funded research databases are useful in finding ongoing studies that are observational or address health services research topics. In these cases, it seems reasonable to check the NIH RePORTER, HSRProj, and/or AHRQ GOLD, depending upon which seems most important to the topic at hand. These sources should be supplemented by targeted searches of the grey literature.

Our brief comparison of the major trial registries and a major funded research database demonstrated that publication rates appear to be higher for ongoing studies identified through the NIH RePORTER than those identified in ClinicalTrials.gov. This could be an indication that federally sponsored research may be more likely to result in publication as opposed to studies published by any sponsor identified in ClinicalTrials.gov. However, this finding could also have implications relevant to study designs as well. We identified one other potentially misleading data element in reviewing these sources. This includes our observation that the publications listed in ClinicalTrials.gov and especially the NIH RePORTER frequently did not always report the results from the ongoing study description for which they were listed. This was confusing and extends screening time to insure that publications listed are truly relevant to the EPC report. One other observation included that nearly half of studies identified in ClinicalTrials.gov did not appear to be published according to our search results. This observation is consistent with previous research. Our examination seemed to indicate that of the factors we examined, topic and sponsor factors were most obviously associated with publication of results.

This study was largely qualitative and suffers from several limitations. Being qualitative, generalizability to other topics and time frames is not possible. This lack of generalizability is demonstrated by the wide variability across our four topics. Additionally, the time frame examined in this project is at an early stage when trial registration was just beginning to rise. We were constrained to this time frame because when following studies forward, a long followup period is necessary between subject enrollment and publication of study results. We expect time frames after those selected for this project to offer improved reporting of ongoing studies and potentially improved publication rates. There is little research on finding ongoing studies, and it is a topic undergoing rapid change. Additionally, we obtained input from only eight individuals with expertise in the area of finding ongoing studies. Opinions about individual databases were sometimes only informed by one or two questionnaire respondents that had experience with the source. Results should be interpreted as an examination of four topics for one time period, a time period that hopefully provides a fairly pessimistic study of registration, reporting, and identification ongoing studies.

Other limitations to the comprehensiveness of this project should also be recognized. Because Clinicaltrials.gov and the ICTRP were identified as the highest priority sources for identifying ongoing trials, we did not analyze other trial registries. We did not analyze the importance of the posted changes in the protocols in relation to study completeness and publication of the results. We did not conduct a comprehensive search of all abstracts that were presented in the meetings. We did not search for the results of unpublished registered studies on the FDA Web site. Nevertheless, our analyses indicated a substantial difference in publication rates across different topics.

Having the information about current ongoing trials in hand is only part of the process of refining the future research needs discussion of EPC reports. The true potential these studies have to fill a particular research gap rests with the quality of the completed published study or completed study results posted to a trials registry. Therefore, a listing of ongoing studies is incomplete without some assessment of how likely these ongoing studies are to fill the identified gaps. At this point, we have little certainty that the ongoing studies identified will be published in a manner consistent with the published protocols. An improved understanding of this for the EPC topic can assist in determining level of resources to invest in these activities. Aside from the positive trend toward publication of federally funded research when compared to industry funded research and more confidence in topics with several studies as opposed to just one, our research sheds little light on this issue. The authors of evidence-based reports have to list future research needs based upon available evidence and describe the current research in process that may assist in filling those needs. A coherent synthesis of existing and expected evidence should result in a greater understanding of future research needs and the priorities among those needs.