# 3 Results

## Key Question 1

In an effort to collect information about sources of information regarding ongoing studies, the EPC Librarian Ongoing Studies questionnaire first sought to identify practices among EPC librarians and other staff with regard to finding ongoing studies. It appears that searching for ongoing studies is a common practice when working on EPC reports. Nearly all respondents participate in searches for ongoing studies. Three indicated that they always search for ongoing studies while working on EPC reports and five said they sometimes do. Only one respondent indicated never searching for ongoing studies and therefore was not eligible for finishing the questionnaire. The eight respondents who reported searching for ongoing studies were asked generally about the sources they used for these searches. Five respondents always use several sources when searching for ongoing studies and three respondents sometimes use multiple sources. Seven of eight respondents always included CTRs in their searches; one sometimes does. Three always search the grey literature in their searches for ongoing studies; four sometimes do, and one never does.

Many sources were identified that can be used to search for ongoing studies. Several sources were identified by previous studies of clinical trials registries.6,9 However, many mentioned in older studies were no longer in existence. The results from the review of literature identified via MEDLINE^®^ and hand searching, Internet searching, personal communication with an EPC librarian while developing the questionnaire, and the EPC Librarian Ongoing Studies Questionnaire identified over 50 sources including portals, clinical trials registries and other searchable databases for identifying ongoing studies. A listing of the sources we identified for finding ongoing studies appears in Appendix C. The sources most frequently used by respondents to our questionnaire were ClinicalTrials.gov and the ICTRP (Table 1).

Table 1 Data sources used to find ongoing studies

Data Source | Always (n) | Always (%) | Sometimes (n) | Sometimes (%) | Never (n) | Never (%)
Portals
ICTRP | 1 | 11.0% | 6 | 67.0% | 2 | 22.0%
IFPMA | 0 | 0% | 0 | 0% | 8 | 100%
International and National Registries
Clinicaltrials.gov | 7 | 87.5% | 1 | 12.5% | 0 | 0%
ISCTRN | 2 | 25.0% | 1 | 12.5% | 5 | 62.5%
Other government | 0 | 0% | 4 | 50.0% | 4 | 50.0%
Industry
Specific pharmaceutical company | 1 | 12.5% | 4 | 50.0% | 3 | 37.5%
PhRMA clinicalstudyresults.org | 1 | 12.5% | 0 | 0% | 7 | 87.5%
Specialty
Academic | 0 | 0% | 2 | 25.0% | 6 | 75%
Subject specific | 1 | 12.5% | 3 | 37.5% | 4 | 50.0%
Databases of Funded Research
HSRProj | 2 | 25.0% | 2 | 25.0% | 4 | 50.0%
RePORT | 3 | 37.5% | 0 | 0% | 5 | 62.5%
AHRQ GOLD | 1 | 12.5% | 1 | 12.5% | 6 | 75%
Specific Foundations | 0 | 0% | 2 | 28.6% | 5 | 71.4%

### Clinical Trials Registries and Databases

The major sources for finding ongoing studies identified in the literature were used in developing the questionnaire. The number of sources available for finding information on ongoing studies demonstrates that searching for ongoing studies can be extremely time consuming. This is one reason we sought guidance from librarians and other EPC staff, to identify which of the resources provide the greatest yield and efficiency in these searches. EPC staff were asked which sources they used in searching for ongoing studies. Clinicaltrials.gov was the most commonly used source. All of the survey respondents that search for ongoing studies (n=8) reported using ClinicalTrials.gov and reported on its attributes.

Opinions based on experience with ClinicalTrials.gov:

- Was easy to use (6/8 respondents agreed, 2/8 were neutral)
- Provided adequate instructions (6/8 respondents agreed, 2/8 were neutral)
- Provided a sufficient amount of information on the trials (6/8 respondents agreed, 2/8 were neutral)
- Appeared to provide a comprehensive listing of studies (5/8 respondents agreed, 2/8 were neutral, 1/8 strongly disagreed)

Valuable or beneficial attributes of ClinicalTrials.gov:

- Straightforward (mentioned by 1 respondent)
- Comprehensive study status (mentioned by 1 respondent)
- Ability to download the trials’ data (mentioned by 2 respondents )
- Ability to customize the search and display (mentioned by 1 respondent)

Difficult or frustrating attributes of ClinicalTrials.gov:

- Out-of-date information (mentioned by 1 respondent)
- Inability to directly perform certain searches, such as searching for only completed trials (mentioned by 1 respondent)
- Not yet comprehensive (mentioned by 1 respondent)
- Can be frustrating to figure out which reports have been published (mentioned by 1 respondent)

Advice offered regarding searching ClinicalTrials.gov:

- Create a filter to import downloaded results into EndNote.
- Drop down menu for downloading format on the search results page.

The second most commonly used source for finding ongoing trials was the ICTRP. However, users of the portal were not as positive as the users of ClinicalTrials.gov. One respondent reported always and six reported sometimes using the ICTRP when searching for ongoing studies. Only six completed questions regarding their experience with the ICTRP.

Opinions based upon experience with the ICTRP:

- Was easy to use (1/6 respondents agreed, 2/6 were neutral, 1/6 disagreed)
- Provided adequate instructions (5/6 respondents were neutral, 1/6 disagreed)
- Provided a sufficient amount of information on the trials (3/6 respondents agreed, 3/6 were neutral)
- Appeared to provide a comprehensive listing of studies (3/6 respondents agreed, 2/6 were neutral, 1/6 disagreed)

Valuable or beneficial attributes of the ICTRP:

- Lists the registry it came from and study contact information (mentioned by 1 respondent)
- Nice to have one place to search (mentioned by 1 respondent)
- Trust in World Health Organization to keep track of national registries (mentioned by 1 respondent)
- Ability to sort list of studies by column (mentioned by 1 respondent)
- Good way to get to non-U.S. registries (mentioned by 1 respondent)

Difficult or frustrating attributes of the ICTRP:

- Different results when searching home page vs. advanced search page with same search terms (mentioned by 1 respondent)
- Out of date information (mentioned by 1 respondent)
- Exporting results (mentioned by 1 respondent)
- Limiting searches (mentioned by 1 respondent)
- Overlap with ClinicalTrials.gov (mentioned by 1 respondent)

Advice offered regarding searching the ICTRP:

- Sorting by registry helps to quickly bypass registries already searched

Industry and specialty registries or databases were also occasionally utilized by EPC librarians and staff. The only industry database mentioned specifically was the clinical study results database maintained by the PhRMA. While specific pharmaceutical company registries were not mentioned, two respondents indicated that they would specifically search a certain company’s registry if they were looking for trials on a particular drug. Specific specialty sources used by questionnaire respondents included the National Cancer Institute registry and a “breast cancer registry.”

### Funded Research Databases

CTRs are useful for identifying ongoing clinical studies. However, many EPC reports address health services research topics. Databases of funded research are a more recent source for identifying these types of ongoing studies. Literature discussing databases that index observational or ongoing health services research studies was not found. Prior knowledge, consultations with librarians, and internet searches identified several sources for identifying ongoing funded research studies. These sources were included in our EPC Librarian Ongoing Studies Questionnaire to assess experience and opinions regarding using these sources.

Half of the questionnaire respondents had used the National Library of Medicine’s Health Services Research database, HSRProj.

Opinions based upon experience with HSRProj:

- Was easy to use (3/4 respondents agreed, 1/4 strongly agreed)
- Provided adequate instructions (2/4 respondents were neutral, 1/4 agreed, 1/4 strongly agreed)
- Provided a sufficient amount of information on the trials (1/4 respondents disagreed, 1/4 were neutral, 1/4 agreed, and 1/4 strongly agreed)
- Appeared to provide a comprehensive listing of studies (3/4 respondents were neutral, 1/4 agreed)

Valuable or beneficial attributes of HSRProj:

- Similar to other National Library of Medicine databases (mentioned by 1 respondent)

Difficult or frustrating attributes of HSRProj:

- Inability to download results (mentioned by 1 respondent)

Advice offered regarding searching HSRProj:

- Able to tag files for downloading.

The National Institute of Health’s Research Portfolio Online Reporting Tool (RePORTER) database was also utilized by a few questionnaire respondents. Three of the eight EPC librarians or staff responded that they always search RePORTER when searching for ongoing studies. The other five had never used the database.

Opinions based upon experience with RePORTER:

- Was easy to use (1/3 respondents strongly disagreed, 1/3 agreed, 1/3 strongly agreed)
- Provided adequate instructions (1/3 respondents strongly disagreed, 1/3 agreed, 1/3 strongly agreed)
- Provided a sufficient amount of information on the trials (1/3 respondents disagreed, 1/3 agreed, 1/3 strongly agreed)
- Appeared to provide a comprehensive listing of studies (1/3 respondents were neutral, 1/3 agreed, 1/3 strongly agreed)

Valuable or beneficial attributes of RePORTER:

- Provides information not available elsewhere (mentioned by 1 respondent)

Difficult or frustrating attributes of RePORTER:

- Very difficult to use, limited searching and downloading capabilities (mentioned by 1 respondent)

Advice offered regarding searching RePORTER:

- Breaking results into smaller groups helps with downloading.

The last specific database of funded research listed on the questionnaire was the Agency for Healthcare Research and Quality’s AHRQ GOLD. Only two respondents reported having used this database, but responses were positive regarding ease of use, adequacy of instructions, sufficiency of data, and comprehensiveness. The one comment provided about this database describes that because it is a small database, it is fairly quick and easy to search.

Other nongovernmental funding organizations mentioned by one respondent, included the “Breast Cancer Research Foundation,” the “Flight Attendant Medical Research Institute,’ and the “Komen Foundation,’ This respondent also described her process in identifying potential funding sources and therefore lists of funded research from which to search for ongoing studies. She uses her institution’s grants listing and performs a topic search to identify topic-specific funding agencies. She then searches the websites of these sponsors individually to identify ongoing studies relevant to that topic.

### Grey Literature

Questionnaire respondents also reported that they frequently performed searches of the grey literature to identify ongoing studies. Of those conducting searches for ongoing studies, five respondents (62.5 percent) reported “always” and three (37.5 percent) reported “sometimes” searching the grey literature to identify ongoing studies. Strategies used to find grey literature, other than that included in the sources previously mentioned, included internet searches from a search engine such as Google, relying on the EPC Scientific Research Center to provide packages of grey literature, conference abstracts, obtaining recommendations of relevant sources for information from experts. Web of Science was also mentioned as an excellent resource for locating conference abstracts. While not mentioned on our questionnaire, we have found that the Cambridge Scientific Abstracts’ Conference Paper Index database is another useful source in identifying conference abstracts. Other sources identified by questionnaire respondents as useful in these searches included the Food and Drug Administration databases, the Grey Literature Report, and topic-specific scientific meeting abstracts.

## Key Question 2

### Research Gaps in Published Evidence-based Reports

We first assessed the population of reports published in 2004–2005 to gather additional information on which to base the selection of the four studies with research gaps to use to identify ongoing studies and follow forward in time to completion and/or publication. Of the 49 EPC reports completed in 2004–2005 (Appendix Table B1), 46 included future research recommendations. The reports did not search for ongoing studies when making research recommendations. One report mentioned an ongoing project that should be available in the near future to fill some evidence gaps pertaining to that topic.34 The number of ongoing studies that we retrospectively identified as relevant at the time when the reports were completed varied across topics without visible patterns. The four EPC reports selected to follow forward in time included:

- Pharmacological treatments of Dementia32
- Acute Stroke: Evaluation and Treatment33
- Islet Transplantation in Patients with Type 1 Diabetes Mellitus34
- Strategies for Improving Minority Healthcare Quality35

### Evaluation of the Databases Searched for Ongoing Studies

In addition to the general information about databases presented for Question 1, here we present more pragmatic evaluation of the data sources used to identify ongoing studies. Funded research databases provided title and a short description about funded studies. Not all funded studies were registered. Only one funded research database, the NIH RePORTER, has a complete list of all grants sponsored by NIH. Trial registries provided more detailed protocols of the registered studies. Trial registries do not have information about all funded studies. More complete information about funded and registered studies was available by combining these two sources (Table 2). One registry, ClinicalTrials.gov, and one funded research database, NIH RePORTER, allowed a sufficiently efficient search by specific conditions or study type. Retrieved data can be downloaded from ClinicalTrials.gov and each of the three funded research databases we evaluated (NIH RePORTER, HSRProj, and AHRQ GOLD).

Table 2 Evaluation of the databases to search for ongoing studies

| Search Terms | Data Downloadable | Grant No. | Lists Publications | Provided Registration Status | Allow Results Posting | Comprehensive When Compared to Other Sources
Registries
ClinicalTrials.gov | Yes | Yes | No | Yes | | Yes | No
ICTRP | No | No | No | No | | No | No
ISRCTN Current Controlled Trials | No | No | No | Yes | | No | No
PhRMA study results | No | No | No | No, references in slides | Link to registry | Yes | No
IFPMA Clinical Trials Portal | No | No | No | No | Link to registry | No | No
Funded Research Databases
NIH RePORTER | Yes | Yes | Yes | Yes but not accurate | No | No | Yes
Foundation Directory Online (FDO) | Yes | Yes | Yes | No | No | No | No
HSRProj | No | Yes | Yes | No | No | No | No
AHRQ GOLD | No | Yes | Yes | Yes but not accurate | No | No | No

Trial registries provide sponsor name but not specific grant numbers. Funded research databases do not provide study registration status. In general, trial registries and grant databases do not have a single variable identifying funding and registration of the same studies. One registry, ClinicalTrials.gov, complies with WHO minimum dataset requirements providing detailed study design, recruitment activities, ethics review of research, target sample size, conditions of eligibility for subjects to participate in the study, and primary and secondary outcomes.21 ClinicalTrials.gov also links to publications indexed in MEDLINE ^®^via PubMed ^®^. The NIH RePORTer, has links to all publications in which the grant was mentioned. However, these links often were not directly related to the exact study that was funded. ClinicalTrials.gov and ClinicalStudyResults.org allow posting of study results.

Searches for ongoing studies in different databases varied in the proportion of relevant studies from those retrieved with a simple subject search (Table 3). Generally, searches in ClinicalTrials.gov were the most efficient. Searches in the ICTRP yielded a small number of eligible studies in addition to those already identified in ClinicalTrials.gov. Searches in funded research databases yielded a large number of funded research studies with small proportions of funded research relevant to answer treatment related research questions.

Table 3 EPC report-specific retrieval and relevance of results

| Pharmacological Treatments for Dementia | | | Islet Transplantation | | | Acute Stroke: Evaluation and Treatment | | | Strategies for Improving Minority Healthcare Quality
| N | n | % | N | n | % | N | n | % | N | n | %
ClinicalTrials.gov | 408 | 47 | 12 | 91 | 22 | 24 | 211 | 44 | 21 | 234 | 80 | 34
ICTRP (in addition to www.clinicaltrials.gov) | 1 | 1 | 100 | 1 | 1 | 100 | 4 | 4 | 100 | 6 | 6 | 100
NIH RePORTER | 1160 | 160 | 14 | 125 | 40 | 32 | 2082 | 464 | 22 | 2 | 1 | 50
HSRProj | | | | | | | | | | 24 | 24 | 100
AHRQ GOLD | | | | | | | | | | 2,797 | 127 | 5

N =number of retrieved studies; n=number of relevant studies; %=percentage of relevant among retrieved.

### Evaluation of Completeness and Publication of the Studies

Information about study completion was available in trial registries. Relevancy of studies retrieved to topic varied across topics and databases (Table 3). The completeness rates (participants are no longer being examined or treated) were analyzed for registered studies only. The majority of registered studies were completed. Completion rates were high for studies determined relevant. All relevant studies of pharmacological treatments for dementia, 99 percent of the relevant studies on quality of care in minority groups, 86 percent of the relevant studies of diagnosis and treatments for acute stroke, and 77 percent of the relevant studies of islet cell transplantation were completed from the time of the EPC report publication and July 2010 (Appendix D).

Publications of ongoing studies were analyzed separately for studies registered in ClinicalTrials.gov (Figure 1) and studies found in the NIH RePORTER (Figure 2). Publications percentages, calculated as the proportion of studies with related publications indexed and identified in MEDLINE^®^, were generally lower for studies registered in ClinicalTrials.gov than for the NIH sponsored studies. For instance, the publication rate for the studies of pharmacological treatments for dementia was 99 percent according to the flags in the NIH grants database but 62 percent among studies registered in ClinicalTrials.gov. Publication rates were less than 50 percent among registered studies of diagnosis and treatments for acute stroke (46 percent), islet cell transplantation (36 percent), or quality of care in minority populations (43 percent). The NIH RePORTER provided publications for more than 80 percent of the studies of diagnosis and treatments for acute stroke (87 percent) and islet cell transplantation (83 percent). The publication rate in the NIH RePORTER was lowest for quality of care in minority populations (50 percent). The NIH RePORTER lists all publications where the grant number was mentioned. Many of the publications do not appear to be directly related.

Figure 1 Proportion of relevant studies (registered in ClinicalTrials.gov) published in peer- reviewed journals

Figure 2 Proportion of relevant studies (sponsored by NIH) published in peer-reviewed journals

### Characteristics of Ongoing Registered Studies

We also examined the characteristics of the registered ongoing studies relevant for the four selected topics. The majority of ongoing studies recruited both sexes. Recruitment of age subgroups depended solely on the topic.

The majority of ongoing studies we identified for the four topics we evaluated recruited adults or seniors. Inclusion of age subgroups depended on the research topic. The majority of registered ongoing studies were interventions. However, observational design was used in 24 percent of ongoing studies of quality of care improvement in minorities. Study design of the studies identified in the NIH RePORTER was difficult to judge because the database does not provide detailed information about study characteristics. More than 80 percent of registered ongoing studies across all four topics posted changes to study protocols. A judgment about the significance of the impact of such changes on the results of the studies was difficult to determine without a time consuming evaluation of archived records for each change and for each study. This was considered beyond the scope of the current research. Less than 5 percent of the ongoing studies across the four topics had the results posted in ClinicalTrials.gov. As we noted before, publication rates of registered studies differed slightly across the four topics. We compared publication status among topics and sponsorship category for the four selected EPC report topics (Table 4). Publication rates varied across topics and by sponsorship category within topics.

Table 4 Summary tables

Distribution of publication status by study topic and sponsor

Study Topic and Sponsorship | Not Published | Published | % Published in Peer Reviewed Journals
Pharmacological Treatments for Dementia
Total Ongoing Studies | 18 | 29 | 62
By source of Funding^*^
Federal Government | 7 | 20 | 74
Nongovernment, nonprofit | 0 | 3 | 100
Industry | 11 | 6 | 35
Acute Stroke: Evaluation and Treatment
Total Ongoing Studies | 24 | 20 | 45
By Source of Funding
Federal Government | 4 | 4 | 50
Nongovernment, nonprofit | 9 | 5 | 36
Industry | 11 | 11 | 50
Islet Transplantation in Patients with Type 1 Diabetes Mellitus
Total Ongoing Studies | 13 | 8 | 38
By Source of Funding
Federal Government | 1 | 2 | 67
Nongovernment, nonprofit | 9 | 6 | 40
Industry | 3 | 0 | 0
Strategies for Improving Minority Healthcare Quality
Total Ongoing Studies | 41 | 31 | 43
By Source of Funding
Federal Government | 23 | 24 | 51
Nongovernment, nonprofit | 15 | 7 | 32
Industry | 3 | 0 | 0

* Source of funding was downloaded from ClinicalTrials.gov

The NIH RePORTER provides complete information about NIH grants but very few details about study design and protocols. Completeness rates were high for all topics. When we compared publication status of the studies that were relevant to different topics, we found out that publications seemed to vary depending on the topic and on the registration status. Publication rates were higher among the studies found in NIH RePORTER than those found in ClinicalTrials.gov. The NIH RePORTER lists all publications that mention the particular grant or funded study. However, in our examination these listed publications frequently did not report results from the particular ongoing study from which the link was obtained. For instance, the funded study aimed to test treatment effects, but linked publications did not report the results of the tested hypothesis.

Nearly half of registered studies did not appear to be published at the time of our search. Ongoing studies that focused on subpopulations seemed to be published less often. Sponsor factors seemed most obviously associated with the publication of the study results.