# 2 Methods

## Key Question 1

Addressing the first key question regarding identifying sources for ongoing studies involved two activities. First, we reviewed the literature discussing ongoing studies and databases or other resources that could be searched to identify ongoing studies. The literature search was conducted in Ovid Medline using the MeSH heading “Clinical trials as topic and the multipurpose key word ‘trials’ regist?” This electronic database search was complemented with hand searching the reference lists of included articles. Literature was searched through July of 2010.

Prior knowledge and the literature searches were used to compile a preliminary list of sources for finding ongoing studies. These primarily included trial registries and databases of funded research. The preliminary listing was used to develop an electronic questionnaire for EPC librarians. The questionnaire sought information about their current practices used in searching for ongoing studies and/or funded research when assisting in the development of EPC reports. The librarians or EPC staff members were asked about specific sources for information about ongoing studies and their experience with those sources.

- How do you conduct a search for ongoing studies (what sources are searched [registries, funded research databases, other sources of grey literature]?
- How do you rate the quality and usefulness of the sources you search for ongoing studies (comments and critiques for identified sources)?

The questionnaire was pretested among colleagues at the University of Minnesota. An e-mail requesting participation and a link to the final electronic questionnaire administered via Survey Monkey^TM31^ were sent out on July 20, 2010, to 14 EPC staff identified by AHRQ as librarians or librarian contact persons. Two individuals listed as EPC librarian contacts responded to the request, explaining that their EPC did not routinely use librarians to assist with their searching and that research staff typically performed the searches relevant to EPC reports. When the survey reminder was sent out via e-mail 1 week later, respondents other than librarians were invited to participate. A copy of the questionnaire appears in Appendix A.

The questionnaire included statements regarding the sources used to conduct searches for ongoing studies. In response to these statements, respondents selected ‘always,’ ‘sometimes,’ or ‘never.’ The first set of statements pertained to general procedures about searching for ongoing studies (if they did it, whether they used several sources, and whether these sources included trial registries, databases of funded research, and grey literature). The next series of statements asked about specific sources or a category of sources and the extent to which each of these is used. Respondents indicating usage of a particular source (ClinicalTrials.gov, controlled-trials.org, ICTRP or IFPMA search engines, clinicalstudyresults.org, HSRProj, NIH RePORTER, AHRQ GOLD) by selecting “sometimes” or “always” were asked to agree or disagree on a 5-point Likert scale with statements about that source:

- It is easy to use.
- It provides adequate instructions to assist in searching.
- The data provided about the ongoing studies are sufficient to gain a basic understanding of the research underway.
- It appears to provide a comprehensive listing of studies.

Respondents were also asked open-ended questions about specific attributes of the source that they found valuable or beneficial and/or difficult or frustrating. They were also asked for advice they could offer regarding the source. Due to the number of registries available, those detailed questions were not asked of all identified sources for ongoing studies. Other registries were asked about in a categorical fashion (government registries other than U.S., professional organization/condition specific registries, academic institution registries, and specific pharmaceutical company registries). If respondents used one of these categories of registries, they were asked to list the specific registry they had used and why. The next section of the survey asked about general approaches to using grey literature to identify ongoing studies and what sources were frequently used for these searches. Lastly, respondents were asked to list other sources they knew of for finding ongoing studies and were provided the opportunity to list other information or comments relevant to finding ongoing studies. From the 14 EPC contacts, we received nine responses for a response rate of 60 percent.

## Key Question 2

Two sequential tasks were completed to address the second research question. First, we analyzed whether completed and published evidence-based reports identified the research gaps. We made a list of reports completed in 2004–2005. We wanted to ensure that evidence reports published after 2004 (when trial registration became more prevalent) are evaluated. We checked to see whether the reports included future research recommendations and in what format (e.g. narrative, list of gaps based on available evidence).

To select topics for the second task of this research question, we searched ClinicalTrials.gov to identify studies relevant to each EPC report topic that were ongoing at the time of report publication. This was necessary to ensure that the reports selected to follow relevant ongoing studies forward to completion and publication included a variety of topics and interventions and had a fairly high amount of ongoing research. A table describing these first steps of quantifying ongoing studies related to each EPC report published in 2004/2005 appears in Appendix B.

Second, we selected four EPC reports representing different areas of comparative effectiveness research, including pharmacological and surgical treatments, diagnostic studies, and health services research. We looked for ongoing studies relevant to those four reports in several sources that were identified through the literature and the librarian questionnaire. The trials registries included ClinicalTrials.gov and the International Standard Randomized Controlled Trial Number (ISRCTN) registry. Additionally, we searched the industry-sponsored database of clinical study results. We searched several websites with information about funded studies including the NIH RePORTER database, the Foundation Directory Online, the National Information Center on Health Services Research and Health Care Technology, Web site, and AHRQ grants On-Line Database (AHRQ GOLD). We selected four reports representing high priority research areas for AHRQ and high research activity.

Using the four selected topics, we evaluated the databases where ongoing studies could be identified. We evaluated the databases using the following criteria:

- What is the search capability (vocabulary used for indexing, advanced searching, Boolean operators, keyword searching only, etc.)?
- Can identified information about studies be downloaded for efficient analysis?
- Do trial registries provide grant numbers to link registries and funding agencies’ databases?
- Do databases provide completion dates for the studies and links to publications in peer reviewed journals?
- Is the data provided complete in each database when compared to other databases?

We retrieved the studies that were ongoing at the time when the EPC reports were published; inclusion criteria for the ongoing studies were similar to the inclusion criteria for the published EPC reports. We used similar search strings to those used in the original report to identify and retrieve ongoing studies. Then we individually reviewed available information about each ongoing study to decide relevance to the published EPC reports. One author screened retrieved studies and subjectively determined their relevance to the EPC reports and inclusion into analysis. We followed these included studies forward in time to the present to evaluate study completion and publication. We defined study status according to the status mentioned in the trial registry or funded research database:

- Completed: the study has concluded normally; participants are no longer being examined or treated (i.e., last patient's last visit has occurred).
- Suspended: recruiting or enrolling participants has halted prematurely but potentially will resume.
- Terminated: recruiting or enrolling participants has halted prematurely and will not resume; participants are no longer being examined or treated.
- Withdrawn: study halted prematurely, prior to enrollment of first participant.

Then we examined completeness and publication rates of ongoing studies. We also analyzed study or sponsor characteristics associated with a publication of the ongoing studies. We separately analyzed publication of the study in peer reviewed journals versus a presentation of the results in scientific meetings. We looked at the publication status of ongoing studies in the database in which we found them. We also searched for publications indexed in MEDLINE^®^ using study identifiers from either the registries or grant numbers from funded research databases. We searched the Cambridge Scientific Abstracts’ Conference Paper Index and Web of Science databases (using both study title and study identifiers from registries and grant numbers from funded research databases) to find out whether the identified ongoing studies were presented at scientific meetings. Conference and meeting abstracts were treated separately from publications, as many studies presented in abstracts may not go on to be published in journals. We qualitatively compared proportions of published and unpublished registered studies by sponsorship and topic.