# 1 Background

The conclusion of each Evidence-based Practice Center (EPC) report typically presents a set of research recommendations based on the research gaps identified in the review. These recommendations can address new interventions, outcomes, populations, or analyses. One useful adjunct to these recommendations would be an analysis of the research that is currently in the pipeline. In effect, this analysis would help to refine the research gaps remaining after accounting for those gaps currently addressed by ongoing studies. This additional information can be used to prioritize the research gaps in the report. Identified research gaps pertaining to issues for which several large studies are underway can be described as a lower priority future research need. Identified research gaps with few studies underway may rise as priorities for future research. Prioritizing the research gaps this way can guide funding agencies in their funding decisions to best fill high priority research gaps and can also provide indications for updating the review.

The Cochrane handbook describes the importance of identifying ongoing studies as part of the process of completing systematic reviews.2 A table called “4.6.5. Characteristics of Ongoing Studies” is used to include identified related ongoing studies in the analysis.2 Unfortunately, several limitations restrict the extent that ongoing studies can be relied upon to fill a particular research gap. For instance, not all ongoing studies are completed or completed as planned. Studies that are completed are not always published. Studies that are published may significantly change their protocols such that they no longer fill the identified research gap.

The value of providing information about ongoing studies depends on the quality of the information available on the ongoing study. Ideally, available information regarding ongoing studies should be efficiently identifiable and sufficient to allow judgment about its likelihood to be completed and published as planned. Additionally, information about the study that helps predict the eventual study quality would also be beneficial. Therefore, ongoing studies can be listed along with an assessment of their potential to fill the research gap and the likelihood of completion and publication.

This project aims to provide insight to EPCs in finding ongoing studies by identifying the key resources, the most efficient approach to these sources and predictors that may help to determine the degree of reliance on a particular study to fill the identified research gap. Finding information about research studies underway but not (yet) published has long been challenging. For several reasons, searching for these studies has become faster and easier. The electronic age, pushes toward openness, transparency, and full disclosure, and studies demonstrating bias in published medical literature have all led to improved access to information on ongoing studies.

## Development of Sources for Finding Information About Ongoing Studies

Progress toward increased access to information about ongoing studies began with a focus on clinical trials. In 1997 the U.S. Food and Drug Administration Modernization Act (FDAMA 113) required NIH to establish a registry of clinical trials for both federally and privately funded trials of experimental treatments for serious or life threatening diseases.3 A Clinical Trials Registry (CTR) is a database of planned, ongoing, or completed clinical trials, published as well as unpublished, in which details concerning the trial’s objectives, main design features, sample size, and tested treatments are stored.4 ClinicalTrials.gov was created and launched in February 2000.^5^ Trial registration was required only for certain trials, those conducted under U.S. Food and Drug Administration investigational new drug applications that evaluate drug efficacy for serious diseases.5 However, few consequences resulted from not registering,6 and registration rates were initially poor. Research on oncology trials found that only 16 of 20 qualifying trials were registered.6

In September 2004, in an effort to improve the registration, the International Committee of Medical Journal Editors (ICMJE) required that clinical trials be registered as a condition for publication in member journals.5 Trials beginning after July 1, 2005, had to be registered in a publically available registry before beginning enrollment. Trials that began enrollment prior to July 1, 2005, were given a deadline of September 13, 2005, to register their trials in a registry.7

Authors were permitted to register trials in any registry that met certain qualifications. At that time, only ClinicalTrials.gov met the registry requirements of being publicly available for no cost, was managed by a not-for-profit organization, included a mechanism to ensure validity, and was electronically searchable.7 To raise awareness of this new requirement, an editorial with the statement requiring registration for publication was authored by 11 medical journal editors and published in several medical journals, including the Annals of Internal Medicine, the Journal of the American Medical Association, the New England Journal of Medicine, The Lancet, and others. This action by the ICMJE inspired a dramatic increase in trial registration. The number of trials registered in Clinicaltrials.gov went from just over 13,000 to over 22,000 one month after the policy went into effect.8

The pharmaceutical industry also responded to calls for greater transparency. In 2004 a U.S. based pharmaceutical trade organization, the Pharmaceutical Research and Manufacturers of America (PhRMA), created a registry for trial results. In 2005 the International Federation of Pharmaceutical Manufacturers and Associations (IFPMA), a global trade group, issued a position paper committing to trial registration consistent with FDAMA 113.^6^ This group also recommended the reporting of results of clinical trials.

Shortly after adding the trial registration requirement for publication, the ICMJE recommended that trial registrations comply with the WHO minimum dataset.6,9 This minimum set of data includes:

- Primary registry and trial identification number
- Trial registration date
- Secondary identification numbers
- Sources of funding
- Primary sponsor
- Secondary sponsor
- Responsible contact person
- Research contact person
- Study title (brief)
- Official title
- Research ethics review (yes/no)/countries of recruitment
- Health condition or problem studied
- Intervention
- Inclusion and exclusion criteria
- Study type
- Anticipated date of first enrollment
- Target sample size
- Recruitment status
- Primary outcome
- Secondary outcome(s)

In September 2007 the Food and Drug Administration Amendments Act (FDAAA) 801 expanded the scope of clinical trial registration to include all drug and device trials (except early phase trials) and add results to the database.5 The expanded scope of registration requirements went into effect in December 2007. Registration rates in ClinicalTrials.gov grew in response to this legislation. A National Library of Medicine spokesman estimated an increase from about 250 trial registrations a week to 350.^10^ Additional components of this legislation went into effect at later dates; results reporting in September 2008; and adverse events reporting in September 2009. Penalties for noncompliance with FDAAA 801 could result in loss of grant funding and daily fines.10 The secretary of Health and Human Services is expected to advise on enhancing results reporting in late 2010.^5^

Other factors improved access to information on clinical trials. In May of 2007 WHO launched its ICTRP. While not a registry, this site offers a search engine allowing users to search several registries simultaneously.10 Another search engine enabling users to find trial registration and results information in several registries was established by IFPMA in 2005.^6^

## Studies of Clinical Trials Registries

As previously mentioned, information about ongoing clinical trials was the first to become available and accessible to the public in a systematic way. The number of CTRs and the number of registered trials has multiplied during the last several years. As the number of CTRs, registered trials, and policies regarding trial registration grew, so did research on CTRs. Incomplete and vague information about the trials seemed to be common as trial registration was gaining acceptance.11,12 Findings from some of these studies suggest that many study results are never published, especially those with negative or insignificant results;13–17 time to publish is longer for insignificant results and study outcomes and protocols may be adjusted based upon study results for publication purposes.13 While publication rates of registered trials were generally low, those sponsored by industry were less likely to be published than those sponsored by government/nongovernment sources.13,16 Several studies find evidence of selective reporting of outcomes in published studies, providing an indication that published reports may have different primary outcomes as a result of study results than is described in registered study protocols.13,18 One recent study found that selective outcome reporting is prevalent in published studies when compared to the trial registration, and only 45 percent of studies were registered before the end of the trial.18 The proportion of trials registered was greater for studies published in general medicine journals compared with specialty journals; and authors identified 69 trials published in journals that specifically mention in their instructions to authors that registration is a requirement for publication that were not registered.18 While the movement toward improved access to information about ongoing trials is not yet perfect, information is more freely available and accessible than ever before.

CTRs are not a new concept. Several authors describe inventories of CTRs. Easterbrook19 reports on results of a 1989 international survey of organizations and individuals known to be active in the field of clinical trials in 13 countries to create a directory of clinical trials registries. Survey results include the identification of 24 current and six planned registries. Registries were developed as early as 1974. Subject-specific registries were prevalent, especially in AIDS/HIV and Cancer.19 Most registries were based in the United States, including two general clinical trials registries collecting information on clinical trials at the national level (one at NIH and one at the Veterans Administration).19 These registries collected information on trials primarily through funding agencies and surveys of organizations known to conduct trials. While many of these registries are no longer in existence, they likely set the stage for current clinical trials registries.

A report by the Public Citizen’s Health Research Group included a listing of four public registries and 18 private registries.20 A study of registry compliance with WHO minimum dataset requirements used a convenience sample of 21 registries.9 They categorize their registries as international, national, specialty, and industry. Web sites for search portals list their registry sources.21,22

The most widely recognized international clinical trials registries include Clinicaltrials.gov and the ISRCTN registry. This is not surprising given that these are the two largest clinical trials registries. In July of 2010 ClinicalTrials.gov listed nearly 95,000 studies and ISRCTN listed over 9,000 studies.23,24 However, in addition to these, international or national trial registries are administered by governments in other countries, including Australia and New Zealand, China, Germany, India, Iran, Japan, Korea, The Netherlands, Pan African countries, and Sri Lanka.21

In addition to the international and national registries, the pharmaceutical industry has been prolific in the development of trials registries. Several authors describe media attention to unpublished trial information on antidepressant drugs as the impetus behind pharmaceutical companies beginning to create registries.6,25 While the trade group PhRMA was organizing and preparing their database of clinical trial results, a couple of pharmaceutical companies created their own registries. Eli Lilly appears to have created the first independent pharmaceutical company registry which began registering trials initiated by July 1, 2004.^25^ The pharmaceutical company currently known as GlaxoSmithKline and others followed.6 Currently, most of the major pharmaceutical companies appear to maintain registries of their ongoing and completed trials.

Specialty registries or databases are also common sources listing ongoing studies. These include subject-specific, institution-specific, or other special interest collections of ongoing trials. For instance, the University of Michigan maintains a searchable database describing studies currently ongoing at the university.26 The Stroke Center Registry maintains a listing of stroke related trials.27 Many of the specialty databases seem intended to inform and recruit patients and are less valuable for researchers because they often do not provide sufficient information about the study.

Several search portals have been established to allow simultaneous searching of several registries, eliminating the need for individuals to search through all registries to compile their list of studies. WHO developed the International Clinical Trials Registry Platform (ICTRP) Search Portal. Here users can search for trials registered in any of the included registries and obtain links to the full record in the respective registry. The metaRegister of Controlled Trials (mRCT) also administered and available though Current Controlled Trials28 searches at least seven registries including Clinicaltrials.gov and the ISRCTN Register. The IFPMA Clinical Trials Portal allows federated searching of four general trial registries and 24 pharmaceutical registries, including PhRMA’s clinical trials results database.29

Sources other than those including registered clinical trials are also important especially when looking for ongoing observational studies or for ongoing studies relevant to health services research questions. While a recent editorial suggests registering health services research projects in ClinicalTrials.gov,30 currently other databases are more useful in identifying these types of ongoing studies. There are newly available databases that were designed to describe funded research studies. The NIH RePORTeER is a database including all research funded by the National Institutes of Health. A database specific to health services research topics was developed by the National Library of Medicine. Other sponsors also list studies that they have funded. Other topic specific grey literature sources are also important to finding ongoing studies that may not be registered. These may be best identified with assistance from content experts on relevant topic-specific conferences and/or websites.

This project aims to shed light on the best way to approach ongoing studies for EPC reports. The value of this additional information as well as the costs are also described.

## Key Questions

To shed light on the value and process of searching for and including ongoing studies in EPC reports, this project set out to address the following key questions:

1. What sources of information are available to identify ongoing studies?
  a. Is the metadata provided, and are indexing and search capabilities in these sources easy to use and understand in identifying studies pertaining to specific research questions?
  b. What are the strengths and weaknesses of these sources?
2. For research questions pertaining to research gaps identified in past EPC reports, how often do these information sources list relevant ongoing studies?
  a. What proportion of registered studies yield publications?
  b. Can study characteristics predict which studies will be completed as planned and published in a timely manner (sponsorship, topic area, etc.)?