# Appendix E Sponsors of Eligible Ongoing Studies

Table E1 Sponsors of the ongoing studies that were relevant to selected evidence-based reports

Categories | Dementia | Minority | Stroke | Type 1 Diabetes | Total
Total | 47 | 72 | 44 | 22 | 185
National Heart, Lung, and Blood Institute (NHLBI) | 0 | 7 | 1 | 0 | 8
National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK) | 0 | 5 | 0 | 3 | 8
National Institute of Mental Health (NIMH) | 8 | 0 | 0 | 0 | 8
National Institute of Neurological Disorders and Stroke (NINDS) | 4 | 1 | 3 | 0 | 8
Department of Veterans Affairs | 3 | 0 | 2 | 0 | 5
National Institute on Aging (NIA) | 4 | 0 | 0 | 0 | 4
Forest Laboratories | 2 | 0 | 1 | 0 | 3
Mount Sinai School of Medicine/Agency for Healthcare Research and Quality (AHRQ) | 0 | 3 | 0 | 0 | 3
National Institutes of Health Clinical Center (CC) | 0 | 2 | 1 | 0 | 3
Novartis | 3 | 0 | 0 | 0 | 3
Astellas Pharma Inc./Astellas Pharma US, Inc. | 0 | 0 | 2 | 0 | 2
Bristol-Myers Squibb | 2 | 0 | 0 | 0 | 2
Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD) | 0 | 2 | 0 | 0 | 2
Johnson & Johnson Pharmaceutical Research & Development, L.L.C. | 2 | 0 | 0 | 0 | 2
Johnson & Johnson Pharmaceutical Research & Development, L.L.C./Ortho-McNeil Neurologics, Inc. | 2 | 0 | 0 | 0 | 2
National Cancer Institute (NCI) | 0 | 2 | 0 | 0 | 2
National Center for Complementary and Alternative Medicine (NCCAM) | 1 | 1 | 0 | 0 | 2
National Institute of Environmental Health Sciences (NIEHS) | 0 | 2 | 0 | 0 | 2
National Institute on Aging (NIA)/Alzheimer's Disease Cooperative Study (ADCS) | 2 | 0 | 0 | 0 | 2
National Institute on Drug Abuse (NIDA) | 0 | 2 | 0 | 0 | 2
Ono Pharma | 1 | 0 | 1 | 0 | 2
PAION Deutschland GmbH | 0 | 0 | 2 | 0 | 2
Pfizer | 0 | 0 | 2 | 0 | 2
Sanofi-Aventis | 0 | 0 | 2 | 0 | 2
Transition Therapeutics | 0 | 0 | 0 | 2 | 2
Voyager Pharmaceutical Corporation | 2 | 0 | 0 | 0 | 2
Abbott Vascular | 0 | 0 | 1 | 0 | 1
Agency for Healthcare Research and Quality (AHRQ) | 0 | 1 | 0 | 0 | 1
Alzheimer's Association | 1 | 0 | 0 | 0 | 1
Alzheimer's Disease Cooperative Study (ADCS)/National Institute on Aging (NIA) | 1 | 0 | 0 | 0 | 1
Arkansas Children's Hospital Research Institute | 0 | 1 | 0 | 0 | 1
AstraZeneca | 0 | 0 | 1 | 0 | 1
AVI BioPharma, Inc. | 0 | 0 | 1 | 0 | 1
AZ-VUB/Fund for Scientific Research, Flanders, Belgium/Belgian Government | 0 | 0 | 0 | 1 | 1
AZ-VUB/Vrije Universiteit Brussel/Universitaire Ziekenhuizen Leuven/Universiteit Antwerpen/Erasme University Hospital | 0 | 0 | 0 | 1 | 1
Barts & The London NHS Trust/Asthma UK/Social Action for Health/Department of Health (Service Support)/Noreen Clarke, Professor of Public Health, Michigan University | 0 | 1 | 0 | 0 | 1
Bayer | 0 | 0 | 1 | 0 | 1
Baylor College of Medicine/U.S. Army Medical Research and Materiel Command | 0 | 1 | 0 | 0 | 1
Baylor Research Institute/Baylor University/Diabetes Research Institute, Miami, Florida | 0 | 0 | 0 | 1 | 1
Beth Israel Deaconess Medical Center/Joslin Diabetes Center | 0 | 0 | 0 | 1 | 1
Boston Medical Center | 0 | 1 | 0 | 0 | 1
Bristol-Myers Squibb/Otsuka America Pharmaceutical | 1 | 0 | 0 | 0 | 1
Centers for Disease Control and Prevention/Philadelphia Health Management Corporation | 0 | 1 | 0 | 0 | 1
Centers for Disease Control and Prevention/University of North Carolina | 0 | 1 | 0 | 0 | 1
Children's Hospital Boston | 0 | 1 | 0 | 0 | 1
Complejo Hospitalario Universitario de Albacete/Instituto Ciencias de la Salud, Junta de Comunidades de Castilla-La Mancha | 0 | 0 | 1 | 0 | 1
Danish Heart Foundation/Fonden for Lægevidenskabelig Forskning for Fyns Amt./Novo Nordisk/AJ Andersen og Hustrus Fond/Overlægerådet Legatudvalg/Raimond og Dagmar Ringgård Bohns Fond/Bankdirektør Hans Stener og hustru Agnes Steners legat/Odense University | 0 | 0 | 1 | 0 | 1
Eisai Inc./Pfizer | 1 | 0 | 0 | 0 | 1
Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD)/National Institute on Drug Abuse (NIDA)/National Institute of Mental Health (NIMH)/National Institute on Alcohol Abuse and Alcoholism (NIAAA) | 0 | 1 | 0 | 0 | 1
Federico II University/Azienda Ospedaliera \D Cotugno\ Hospital of Infectious Diseases | 0 | 1 | 0 | 0 | 1
Florida International University/Sigma Theta Tau International (Nursing Honor Society) | 0 | 1 | 0 | 0 | 1
Fuzhou General Hospital | 0 | 0 | 0 | 1 | 1
Gates Malaria Partnership/Yunnan Institute | 0 | 1 | 0 | 0 | 1
Global Biotech | 0 | 0 | 1 | 0 | 1
IRCCS San Raffaele/Fondazione Telethon | 0 | 1 | 0 | 0 | 1
IRCCS San Raffaele/PRIN MIUR/Juvenile Diabetes Research Foundation/Telethon-JDRF Center for Beta cell replacement: clinical core. | 0 | 0 | 0 | 1 | 1
Janssen, LP | 1 | 0 | 0 | 0 | 1
John Douglas French Foundation/Institute for the Study of Aging (ISOA) | 1 | 0 | 0 | 0 | 1
Johns Hopkins University/National Institutes of Health (NIH) | 0 | 0 | 1 | 0 | 1
Kaiser Permanente | 0 | 1 | 0 | 0 | 1
Kantonsspital Baden/407 Doctors | 0 | 0 | 1 | 0 | 1
Kantonsspital Baden/RehaClinic Zurzach | 0 | 0 | 1 | 0 | 1
Lawson Health Research Institute/London Health Sciences Centre | 0 | 0 | 0 | 1 | 1
M.D. Anderson Cancer Center | 0 | 1 | 0 | 0 | 1
Mayo Clinic/Aventis Pharmaceuticals | 0 | 1 | 0 | 0 | 1
McMaster University | 0 | 1 | 0 | 0 | 1
Memorial Sloan-Kettering Cancer Center/National Cancer Institute (NCI) | 0 | 1 | 0 | 0 | 1
Memorial Sloan-Kettering Cancer Center/North General Hospital, New York/Ralph Lauren Center for Cancer Care and Prevention | 0 | 1 | 0 | 0 | 1
Mitsubishi Tanabe Pharma Corporation/Kyowa Hakko Kogyo Co., Ltd. | 0 | 0 | 1 | 0 | 1
National Center for Research Resources (NCRR) | 0 | 1 | 0 | 0 | 1
National Center for Research Resources (NCRR)/Alzheimer's Association/Pfizer/Eisai Inc. | 1 | 0 | 0 | 0 | 1
National Center for Research Resources (NCRR)/University of Alabama at Birmingham | 0 | 1 | 0 | 0 | 1
National Human Genome Research Institute (NHGRI) | 0 | 1 | 0 | 0 | 1
National Institute of Arthritis and Musculoskeletal and Skin Diseases (NIAMS) | 0 | 1 | 0 | 0 | 1
National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK)/National Center for Research Resources (NCRR)/National Institute of Allergy and Infectious Diseases (NIAID)/Eunice Kennedy Shriver National Institute of Child Health and Human Development | 0 | 1 | 0 | 0 | 1
National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK)/National Institute of Allergy and Infectious Diseases (NIAID)/National Center on Minority Health and Health Disparities (NCMHD)/National Cancer Institute (NCI)/Hoffmann-La Roche | 0 | 1 | 0 | 0 | 1
National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK)/National Institute on Aging (NIA)/Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD)/National Center on Minority Health and Health Disparities (NCMHHD) | 0 | 1 | 0 | 0 | 1
National Institute of Neurological Disorders and Stroke (NINDS/Yale University | 0 | 0 | 1 | 0 | 1
National Institute of Nursing Research (NINR) | 0 | 1 | 0 | 0 | 1
National Institute of Nursing Research (NINR)/National Institutes of Health (NIH) | 0 | 1 | 0 | 0 | 1
National Institute on Aging (NIA)/Alzheimer's Disease Cooperative Study (ADCS)/Neuro-Hitech | 1 | 0 | 0 | 0 | 1
National Institute on Aging (NIA)/UCLA Resource Centers for Minority Aging Research/Center for Health Improvement of Minority Elderly (RCMAR/CHIME) | 0 | 1 | 0 | 0 | 1
Novocell/Diabetes & Glandular Disease Research Associates, P.A., San Antonio, TX/CHRISTUS Santa Rosa Healthcare | 0 | 0 | 0 | 1 | 1
Oregon Health and Science University/National Institute on Aging (NIA)/National Center for Complementary and Alternative Medicine (NCCAM) | 1 | 0 | 0 | 0 | 1
Princess Alexandra Hospital, Brisbane, Australia/The Broad Foundation/Townsville Hospital/James Cook University, Queensland, Australia/Walter and Eliza Hall Institute of Medical Research/Queensland Institute of Medical Research | 0 | 1 | 0 | 0 | 1
Pronova Biocare/Danish Heart Foundation/The Danish Kidney Association/North Jutland County | 0 | 0 | 1 | 0 | 1
Royal Perth Hospital/Royal Perth Hospital Medical Research Foundation | 0 | 0 | 1 | 0 | 1
Rush University Medical Center | 0 | 1 | 0 | 0 | 1
Sahlgrenska University Hospital, Sweden/Stockholm South General Hospital/University Hospital Orebro/Norra Alvsborgs Lans Hospital, Trollhattan/Varberg Hospital, Varberg | 0 | 0 | 1 | 0 | 1
Saint Antoine University Hospital/French Cardiology Society | 0 | 0 | 1 | 0 | 1
Sanofi-Aventis/Bristol-Myers Squibb | 0 | 0 | 1 | 0 | 1
Second University of Naples | 0 | 0 | 1 | 0 | 1
Stanford University/Northeastern University | 0 | 1 | 0 | 0 | 1
State University of New York - Upstate Medical University/Bristol-Myers Squibb | 0 | 1 | 0 | 0 | 1
Takeda Global Research & Development Centre (Europe) Ltd./Eli Lilly and Company | 0 | 0 | 1 | 0 | 1
The Cleveland Clinic/Sanofi-Aventis | 0 | 0 | 1 | 0 | 1
The Shiley Family Trust/Institute for the Study of Aging (ISOA)/University of California, San Diego | 1 | 0 | 0 | 0 | 1
Universidad de Antioquia | 0 | 1 | 0 | 0 | 1
University Hospital, Grenoble | 0 | 0 | 0 | 1 | 1
University Hospital, Lille/Institut National de la Santé Et de la Recherche Médicale, France | 0 | 0 | 0 | 1 | 1
University Hospital, Strasbourg, France | 0 | 0 | 1 | 0 | 1
University Hospital, Toulouse/Ministry of Health, France | 0 | 0 | 1 | 0 | 1
University of Alberta/Juvenile Diabetes Research Foundation | 0 | 0 | 0 | 1 | 1
University of California, Irvine | 0 | 1 | 0 | 0 | 1
University of California, Irvine/Juvenile Diabetes Research Foundation | 0 | 0 | 0 | 1 | 1
University of Connecticut Health Center/Agency for Healthcare Research and Quality (AHRQ) | 0 | 1 | 0 | 0 | 1
University of Glasgow/South Glasgow University Hospitals NHS Trust/The Stroke Association, United Kingdom | 0 | 0 | 1 | 0 | 1
University of Hawaii/National Center on Minority Health and Health Disparities (NCMHD) | 0 | 1 | 0 | 0 | 1
University of L'Aquila | 0 | 1 | 0 | 0 | 1
University of Maryland | 0 | 1 | 0 | 0 | 1
University of Minnesota - Clinical and Translational Science Institute/Hoffmann-La Roche/Juvenile Diabetes Research Foundation | 0 | 0 | 0 | 1 | 1
University of Minnesota - Clinical and Translational Science Institute/Juvenile Diabetes Research Foundation | 0 | 0 | 0 | 1 | 1
University of Minnesota - Clinical and Translational Science Institute/Juvenile Diabetes Research Foundation/National Institutes of Health (NIH)/Novartis | 0 | 0 | 0 | 1 | 1
University of Minnesota - Clinical and Translational Science Institute/National Institutes of Health (NIH)/Juvenile Diabetes Research Foundation | 0 | 0 | 0 | 1 | 1
University of North Carolina/National Institutes of Health (NIH)/Indiana University School of Medicine/Wishard Health Services | 0 | 1 | 0 | 0 | 1
University of Oxford/Sanofi-Aventis/AstraZeneca | 0 | 0 | 1 | 0 | 1
University of Pennsylvania | 0 | 1 | 0 | 0 | 1
University of South Carolina/Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD) | 0 | 1 | 0 | 0 | 1
University of Texas Southwestern Medical Center | 0 | 1 | 0 | 0 | 1
University of Tromso/The Research Council of Norway/The Council on Health and Rehabilitation, Norway/The Norwegian Council on Cardiovascular Disease/The Royal Norwegian Ministry of Health/The Norwegian Red Cross/Foundation to Promote Research into Function | 0 | 0 | 1 | 0 | 1
University of Wisconsin, Madison | 1 | 0 | 0 | 0 | 1
University of Zurich/Eli Lilly and Company | 0 | 0 | 1 | 0 | 1
University of Zurich/Schweizerische Herzstiftung/Eli Lilly and Company | 0 | 0 | 1 | 0 | 1
Washington University School of Medicine | 0 | 1 | 0 | 0 | 1
Washington University School of Medicine/National Institute of Environmental Health Sciences (NIEHS) | 0 | 1 | 0 | 0 | 1
Weill Medical College of Cornell University | 0 | 0 | 0 | 1 | 1