# Appendix D Trial Completion by Topic

Figure D1 Proportion of Completed Studies Among All Eligible Studies That Were Registered in ClinicalTrials.gov