# Appendix C Sources for Finding Ongoing Studies

Source for finding ongoing studies Web address
Portals
WHO International Clinical Trials Registry Platform (ICTRP) Search Portal http://apps.who.int/trialsearch
IFPMA Clinical Trials Porta http://clinicaltrials.ifpma.org
mRCT http://www.controlled-trials.com
TrialsCentral http://www.trialscentral.org Not an authoritative site
Centerwatch http://www.centerwatch.com/
International and National
ClinicalTrials.gov http://clinicaltrials.gov
ISRCTN Current Controlled Trials http://www.controlled-trials.com
Australian New Zealand Clinical Trials Registry http://www.anzctr.org.au
Canada Trials http://www.canadatrials.com/
Chinese Clinical Trial Registry http://www.chictr.org
Clinical Trials Registry – India http://www.ctri.in/Clinicaltrials/index.jsp
German Clinical Trials Register http://www.drks.de
Iranian Registry of Clinical Trials http://www.irct.ir
Japan Primary Registries Network http://rctportal.niph.go.jp/link.html
Pan African Clinical Trial Registry http://www.pactr.org
The Netherlands National Trial Register http://www.trialregister.nl
Sri Lanka Clinical Trials Registry http://www.slctr.lk
Industry Clinical Trials
Almirall http://www.almirall.com/webcorp2/cda/ImD_03_02.jsp
Amgen http://www.amgentrials.com/
AstraZeneca http://www.astrazeneca.com/research/our-pipeline-summary/
Bayer HealthCare - Trial Finder http://www.bayerhealthcare.com/scripts/pages/en/research_development/clinical_trials/trial_finder/index.php
Bristol-Myers Squibb http://www.bms.com/research/pipeline/Pages/default.aspx
Genentech http://www.gene.com/gene/pipeline/status/
GlaxoSmithKline http://www.gsk-clinicalstudyregister.com/
Lilly http://www.lillytrials.com/
Merck http://www.merck.com/research/pipeline/home.html?WT.svl=mainnav
Novartis http://www.novartisclinicaltrials.com
Novo Nordisk http://www.novonordisk.com/science/pipeline/rd_pipeline.asp
Roche http://www.roche-trials.com/
Takeda http://www.takeda.com/research/product-pipeline/article_1044.html
Specialty Clinical Trials
AIDS Clinical Trials Group http://www.aactg.org/
Centre for Clinical Trials, Clinical Trials Registry – Chinese University of Hong Kong http://www.cct.cuhk.edu.hk/cctwebsite/Home/tabid/38/Default.aspx
Clinical Trial Registry of the University Medical Center Freiburg http://www.uniklinik-freiburg.de/zks/live/uklregister/Oeffentlich_en.html
European Leukemia Trial Registry http://www.leukemia-net.org/content/e58/e3956/e3957/index_eng.html
German Registry for Somatic Gene-Transfer Trials http://www.dereg.de/dereg_new/dereg_extern/index.faces
Harvard Bipolar Research Program http://www.mainicdepressive.org/currentstudies.php#
National Cancer Institute http://www.cancer.gov/clinicaltrials
North Shore-Long Island Jewish Health System http://www.northshorelij.com/NSLU/Clinical+Trials
PhRMA Clinical Study Results Database http://www.clinicalstudyresults.org/
Stroke Trials Directory http://www.strokecenter.org/trials
University of Alabama Comprehensive Cancer Center http://www2.ccc.uab.edu/CSUWEB/ClinicalTrialsListing.asp
University of California at San Francisco (UCSF) Cancer Center http://medschool.ucsf.edu/clinical_trials/
University of Michigan Clinical Trials https://www.umms.med.umich.edu/engage/disp_pub_condition.do
Winship Cancer Institute of Emory University http://winshipcancer.emory.edu/WinshipContentPage.aspx?nd=759
Health Services Research Ongoing Studies
AHRQ GOLD http://gold.ahrq.gov/projectsearch/
HSRProj (Health Services Research Projects in Progress) http://wwwcf.nlm.nih.gov/hsr_project/home_proj.cfm
NIH REPORT http://report.nih.gov/index.aspx
RWJF http://www.rwjf.org/grants/pg.jsp