# Appendix B EPC Reports Published in 2004/2005

Table B1 Research gaps and ongoing studies in completed evidence-based reports

Study Name | Institution | Includes Future Research Recommendations | Format (Narrative, List, etc.) | Notes | Number of Ongoing Studies: Clinicaltrials.gov | Number of Ongoing Studies: Other Sources
Likely to have clinical trials
Effectiveness of Portable Monitoring Devices for Diagnosing Obstructive Sleep Apnea: Update of a Systematic Review http://www.cms.gov/determinationprocess/downloads/id24TA.pdf | RTI International– University of North Carolina | No | No | Year: 2005 | 0 | 0
RANDOMIZED TRIALS OF SECONDARY PREVENTION PROGRAMS IN CORONARY ARTERY DISEASE: A SYSTEMATIC http://www.cms.gov/determinationprocess/downloads/id31TA.pdf | the University of Alberta Evidence-based Practice Center | Yes | Narrative in Discussion | Year: 2005 | 5 | 0
Usual Care in the Management of Chronic Wounds http://www.cms.gov/determinationprocess/downloads/id37TA.pdf | Tufts-New England Medical Center EPC | No | No | Year: 2005 | 3 | 4
Effectiveness of Antimicrobial Adjuncts to Scaling and Root-Planing Therapy for Periodontitis http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta88 | RTI International– University of North Carolina | Yes | Narrative | Separate chapter of future research | 1 | 1
Health Effects of Omega-3 Fatty Acids on Lipids and Glycemic Control in Type II Diabetes and the Metabolic Syndrome and on Inflammatory Bowel Disease, Rheumatoid Arthritis, Renal Disease, Systemic Lupus Erythematosus and Osteoporosis http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta89 | Southern California/RAND | Yes | List | Year: 2004 | 5 | 1
Health Effects of Omega-3 Fatty Acids on Asthma http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta91 | University of Ottawa | Yes | Narrative | Research Implications and Possibilities Year: 2004 | 0 | 1
Health Effects of Omega-3 Fatty Acids on Arrhythmogenic Mechanisms in Animal and Isolated Organ/Cell Culture Studies http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta92 | Tufts-New England Medical Center | Yes | Tables and narrative | Year: 2004 | 0 | 0
Effects of Omega-3 Fatty Acids on Cardiovascular Risk Factors and Intermediate Markers of Cardiovascular Disease http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta93 | Tufts-New England Medical Center | Yes | List | Year: March 2004 | 4 | 1
Health Effects of Omega-3 Fatty Acids on Cardiovascular Disease http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta94 | Tufts-New England Medical Center | Yes | List | Year: March 2004 | 2 | 1
Pharmacological Treatment of Dementia http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=hserta&part=A140440#A140514 | McMaster University | Yes | List | | 13 | 10
Islet Transplantation in Patients with Type 1 Diabetes Mellitus http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=hserta&part=A148269 | Blue Cross and Blue Shield | Yes | Reports from the Collaborative Islet Transplant Registry (CITR) are expected to be available in the near future. | Discussion includes mention of “uncertainties” that remain, but no explicit research recommendations | 5 | 9
Economic Incentives for Preventive Care http://www.ahrq.gov/clinic/tp/ecinctp.htm | University of Minnesota | Yes | Narrative | Year: August 2004 | 0 | 0
Effectiveness of Behavioral Interventions to Modify Physical Activity Behaviors in General Populations and Cancer Patients and Survivors | University of Minnesota | Yes | Narrative | “Future Direction” | 3 | 14
Pharmacological and Surgical Treatment of Obesity | Southern California-RAND | Yes | Narrative | | 4 | 15
Celiac Disease http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta104 | University of Ottawa | Yes | Narrative | Year: September 2004 | 1 | 4
Cardiac Resynchronization Therapy for Congestive Heart Failure | University of Alberta | see note | | Conclusion notes: “a marked paucity of data exists for the efficacy and complication rates with CRT devices beyond one year”— presumably a possibility for future research | 0 | 1
Preventing Violence and Related Health-Risking Social Behaviors in Adolescents http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta107 | Southern California Evidence-based Practice Center | Yes | Narrative | Future research opportunities was one of the Key Questions Year: October 2004 | 2 | 10
Melatonin for Treatment of Sleep Disorders http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta108 | University of Alberta | Yes | Narrative | Year: November 2004 | 3
Wound-Healing Technologies: Low-Level Laser and Vacuum-Assisted Closure | Blue Cross and Blue Shield | Yes | Narrative | | 0 | 0
Effects of Omega-3 Fatty Acids on Cancer http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta113 | Southern California/RAND | Yes | Narrative | Year: February 2005 | 2 | 0
Effects of Omega-3 Fatty Acids on Cognitive Function with Aging, Dementia, and Neurological Diseases http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta114 | Southern California/RAND | Yes | List | Year: February 2005 | 1 | 2
Effects of Omega-3 Fatty Acids on Organ Transplantation http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta115 | Tufts-New England Medical Center | Yes | List | Year: February 2005 | 0 | 0
Effects of Omega-3 Fatty Acids on Mental Health http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta116 | University of Ottawa | Yes | Narrative | Research Implications and Directions” Year: July 2005 | 5 | 4
Effects of Omega-3 Fatty Acids on Eye Health http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta117 | University of Ottawa | Yes | Narrative | “Research Implications and Directions” Year: July 2005 | 1 | 2
Effects of Omega-3 Fatty Acids on Child and Maternal Health http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta118 | University of Ottawa | Yes | Narrative | “Research Implications and Directions” Year: August 2005 | 0 | 0
Management of Menopause-Related Symptoms http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta120 | Oregon Health & Science University | Yes | Narrative | Roughly 1 sentence on future research per Key Question in “discussion” section Year: March 2005 | 9 | 5
Use of Spirometry for Case Finding, Diagnosis, and Management of Chronic Obstructive Pulmonary Disease (COPD) http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta121 | University of Minnesota | Yes | List | Year: September 2005 | 2 | 0
Post-Myocardial Infarction Depression http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta123 | Johns Hopkins University | Yes | Narrative | One paragraph per Key Question Year: May 2005 | 2 | 5
Manifestations and Management of Chronic Insomnia in Adults http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta125 | University of Alberta | Yes | Narrative | “Limitations of the Review and Future Research” Year: June 2005 | 2 | 2
Acute Stroke: Evaluation and Treatment http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta127 | University of Ottawa | Yes | Narrative | “Research and Clinical Implications” Year: July 2005 | 7 | 2
Diagnosis, Prognosis, and Therapy of Impaired Glucose Tolerance and Impaired Fasting Glucose http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta128 | McMaster University | Yes | Narrative | Year: September 2005 | 6 | 2
Diagnosis and Management of Work-Related Asthma | University of Alberta | Yes | List | | 1 | 4
Percutaneous Myocardial Laser Revascularization and Transmyocardial Laser Revascularization http://www.cms.gov/DeterminationProcess/downloads/id125.pdf | Duke Center for Clinical Health Policy Research and Evidence- based Practice Center | No | No | Year: 2004 | 1 | 2
May have clinical trials
Strategies for Improving Minority Healthcare Quality http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta90 | Johns Hopkins University | Yes | List | Year: January 2005 | 4 | 4
The Use of Episiotomy in Obstetrical Care: A Systematic Review | RTI International- University of North Carolina | Yes | Narrative | | 1 | 0
Update on Acute Bacterial Rhinosinusitis http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta124 | Tufts-New England Medical Center | Yes | Narrative | Year: June 2005 | 0 | 0
Effects of Soy on Health Outcomes http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta126 | Tufts-New England Medical Center | Yes | Narrative | Year: August 2005 | 16 | 19
Gastroesophageal Reflux Disease, Management Strategies (December 2005) http://effectivehealthcare.ahrq.gov/ehc/products/1/42/GERDExecSum.pdf | Tufts-New England Medical Center EPC | Yes | December 2005, Remaining issues | Year: December 2005 | 2 | 0
Unlikely to have clinical trials
Literacy and Health Outcomes http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta87 | RTI International– University of North Carolina | Yes | Narrative | Year: January 2004 | 1 | 18
Training of Hospital Staff to Respond to a Mass Casualty Incident http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta95 | JHU EPC/Johns Hopkins University Bloomberg School of Public Health | Yes | Narrative | Year: July 2004 | 0 | 1
Regionalization of Bioterrorism Preparedness and Response http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta96 | Stanford–UCSF | Yes | Narrative | Year: April 2004 | 0 | 0
Community-Based Participatory Research http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta99 | RTI International- University of North Carolina | Yes | Narrative | Notes that several studies are upcoming (as of publication date) Year: July 2004 | 0 | 0
Criteria to Determine Disability Related to Multiple Sclerosis http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta100 | Duke | Yes | Narrative | Year: May 2004 | 1 | 21
Measuring the Quality of Breast Cancer Care in Women http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta105 | University of Ottawa | Yes | Narrative | Refers to key upcoming study from ASCO Year: October 2004 | 0 | 14
Sexuality and Reproductive Health Following Spinal Cord Injury http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta109 | University of Ottawa | Yes | Narrative | “Research and Clinical Implications” Year: November 2004 | 1 | 2
End-of-Life Care and Outcomes http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta110 | Southern California-RAND | Yes | Narrative with 12 “Considerations” highlighted | Year: December 2004 | 1 | 0
Perinatal Depression: Prevalence, Screening Accuracy, and Screening Outcomes http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta119 | RTI-University of North Carolina | Yes | Narrative | Year: February 2005 | 0 | 6
Knowledge and Access to Information on Recruitment of Underrepresented Populations to Cancer Clinical Trials http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta122 | JHU EPC / Johns Hopkins University Bloomberg School of Public Health | Yes | List | Recommendations and Research Opportunities” Year: June 2005 | 1 | 0