# Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CITR: Collaborative Islet Transplant Registry
CSA: Cambridge Scientific Abstracts
CTR: Clinical Trials Registry
EPC: Evidence-based Practice Center
FDAAA: Food and Drug Administration Amendments Act
FDAMA: Food and Drug Administration Modernization Act
FDO: Foundation Directory Online
ICMJE: International Committee of Medical Journal Editors
IFPMA: International Federation of Pharmaceutical Manufacturers Association
ICTRP: International Clinical Trials Registry Platform
ISRCTN: International Standard Randomised Controlled Trial Number
mRCT: metaRegister of Controlled Trials
NIH: National Institutes of Health
PhRMA: Pharmaceutical Research and Manufacturers of America
RePORTER: Research Portfolio Online Reporting Tool
WHO: World Health Organization