# Whale Fall Community

The metabolic capabilities of terrestrial and marine microbial communities were compared using largely unassembled sequence data obtained by shotgun sequencing DNA isolated from whale fall and soil. The gene content isolated from three whale fall carcasses was compared to environmental sequence data isolated from soil, acid mine drainage, and the Sargasso Sea. Analysis of these metagenomes identified genes that display environment-dependent characteristics, distribution and expression.

## Data

WGS study | Whale fall #1 | AAFY00000000
WGS study | Whale fall #2 | AAFZ00000000
WGS study | Whale fall #3 | AAGA00000000
Contigs | Whale fall #1 | AAFY01000001-AAFY01028151 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AAFY01000001:AAFY01028151%5baccn%5d)
Contigs | Whale fall #2 | AAFZ01000001-AAFZ01029934 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AAFZ01000001:AAFZ01029934%5baccn%5d)
Contigs | Whale fall #3 | AAGA01000001-AAGA01026232 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AAGA01000001:AAGA01026232%5baccn%5d)
Scaffolds | No scaffolds available
Trace data | 117,326 reads (http://www.ncbi.nlm.nih.gov/Traces/trace.cgi?cmd=retrieve&val=ncbi_project_id%3D13700) available from the Trace Archive
16S ribosomal RNA | Whale fall #1 | AY922180-AY922207 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AY922180:AY922207%5baccn%5d)
16S ribosomal RNA | Whale fall #2 | AY922208-AY922232 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AY922208:AY922232%5baccn%5d)
16S ribosomal RNA | Whale fall #3 | AY922233-AY922252 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AY922233:AY922252%5baccn%5d)

25 Mbp of sequence was generated for each whale fall library. It is estimated that between 100-700 Mbp would be needed to generate a draft assembly for the most prevalent genome.

## Isolation Source

Whale carcasses on the sea floor are a rich source of organic matter for organisms that inhabit the ocean depths. This ecological niche, referred to as a “whale fall” may select for unique species within this nutrient-poor environment. In particular, sulfate-reducing bacteria oxidize organic matter, such as the lipid-rich skeleton, producing sulfides that chemosynthetic microorganisms use for energy.

Whale fall #1 | Isolated from a rib bone from a gray whale carcass experimentally sunk in 1998 in the Pacific Ocean, Santa Cruz Basin (N33.30 W119.22) at a depth of 1674 meters
Whale fall #2 | Isolated from an orange microbial mat on a gray whale carcass experimentally sunk in 1998 in the Pacific Ocean, Santa Cruz Basin (N33.30 W119.22) at a depth of 1674 meters
Whale fall #3 | Isolated from a whale bone of uncertain age and species collected by otter trawl on a muddy seafloor at a depth of 560 meters in the Southern Ocean of the West Antarctic Peninsula Shelf (S65.10 W64.47)

## Genome Assembly

None

## Sequence Analysis

BLAST (http://www.ncbi.nlm.nih.gov/projects/genome/seq/BlastGen/BlastGen.cgi?pid=13700) against these contigs.

Genome Project ID: 13700 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?db=genomeprj&cmd=Retrieve&dopt=Overview&list_uids=13700)

## References

Tringe SG, von Mering C, Kobayashi A, Salamov AA, Chen K, Chang HW, Podar M, Short JM, Mathur EJ, Detter JC, Bork P, Hugenholtz P, Rubin EM. Comparative metagenomics of microbial communities. Science 2005, 308: 554-557. 15845853
Whalefall metagenomic data is also available from the U.S. Department of Energy Joint Genome Institute Integrated Microbial Genomes System (http://www.jgi.doe.gov/). Supporting data and an interactive analysis of the soil, whale fall, and Sargasso Sea communities can be found here (http://string.embl.de/metagenome_comp_suppl).