# Waseca County Farm Soil

The metabolic capabilities of terrestrial and marine microbial communities were compared using largely unassembled sequence data obtained by shotgun sequencing DNA isolated from whale fall and soil. The gene content isolated from soil was compared to environmental sequence data isolated from three whale fall carcasses, acid mine drainage, and the Sargasso Sea. Analysis of these metagenomes identified genes that display environment-dependent characteristics, distribution and expression.

## Data

WGS study | AAFX00000000
Contigs | AAFX01000001-AAFX01139340 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AAFX01000001:AAFX01139340%5baccn%5d)
Scaffolds | No scaffolds available
Trace data | 138,347 reads (http://www.ncbi.nlm.nih.gov/Traces/trace.cgi?cmd=retrieve&val=ncbi_project_id%3D13699) available from the Trace Archive
16S ribosomal RNA | AY921654-AY922179 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AY921654:AY922179%5baccn%5d)

100 Mbp of sequence was generated from the soil sample. However, less then 1% of nearly 150,000 reads exhibited overlap with reads from independent clones. It is estimated that 2-5 billion base pairs would be necessary to obtain 8X-coverage for draft genome assemblies.

## Isolation Source

Agricultural surface soil (0-10 cm) was collected in September 2001 from a farm in Waseca County, Minnesota. The surrounding area had been used for livestock, including sheep, cattle, and pigs, and was in the drainage path of a silage storage bunker that had been used for sweet corn and pea silage water operations from 1990-1997. Biochemical analyses on 20g of soil from this site revealed it to be clay loam, with fair to low organic matter content, high levels of essential elements, and low levels of nonessential elements. Microscopic analysis found the organisms in the sample to be primarily prokaryotic.

## Genome Assembly

None

## Sequence Analysis

BLAST (http://www.ncbi.nlm.nih.gov/projects/genome/seq/BlastGen/BlastGen.cgi?pid=13699) against these contigs.

Genome Project ID: 13699 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?db=genomeprj&cmd=Retrieve&dopt=Overview&list_uids=13699)

## References

Tringe SG, von Mering C, Kobayashi A, Salamov AA, Chen K, Chang HW, Podar M, Short JM, Mathur EJ, Detter JC, Bork P, Hugenholtz P, Rubin EM. Comparative metagenomics of microbial communities. Science 2005, 308: 554-557. 15845853
Soil metagenomic data is also available from the U.S. Department of Energy Joint Genome Institute Integrated Microbial Genomes System (http://www.jgi.doe.gov/). Supporting data and an interactive analysis of the soil, whale fall, and Sargasso Sea communities can be found here (http://string.embl.de/metagenome_comp_suppl).