# Mouse Gut Microbiota Metagenome

Comparisons of the distal gut microbiota of genetically obese mice and their lean littermates, as well as those of obese and lean human volunteers have revealed that obesity is associated with changes in the relative abundance of the two dominant bacterial divisions, the Bacteroidetes and the Firmicutes. Comparative metagenomic analyses was used to examine how these changes affect the metabolic potential of the mouse gut microbiome.

## Data

WGS study | Lean mouse 1 (+/+; Litter 1) | AATA0000000
WGS study | Lean mouse 2 (ob/+; Litter 2) | AATB0000000
WGS study | Lean mouse 3 (+/+; Litter 2) | AATC00000000
WGS study | Obese mouse 1 (ob/ob; Litter 1) | AATD00000000
WGS study | Obese mouse 2 (ob/ob; Litter 2) | AATE00000000
WGS study | Combined datasets | AATF00000000
Contigs | Lean mouse 1 (+/+; Litter 1) | AATA0100001-AATA01010733 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AATA01000001:AATA01010733%5baccn%5d)
Contigs | Lean mouse 2 (ob/+; Litter 2) | AATB0100001-AATB01011335 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AATB01000001:AATB01011335%5baccn%5d)
Contigs | Lean mouse 3 (+/+; Litter 2) | AATC01000001-AATC01010377 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AATC01000001:AATC01010377%5baccn%5d)
Contigs | Obese mouse 1 (ob/ob; Litter 1) | AATD01000001-AATD01010948 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AATD01000001:AATD01010948%5baccn%5d)
Contigs | Obese mouse 2 (ob/ob; Litter 2) | AATE01000001-AATE01008828 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AATE01000001:AATE01008828%5baccn%5d)
Contigs | Combined datasets | AATF01000001-AATF01013667 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AATF01000001:AATF01013667%5baccn%5d)
Scaffolds | No scaffolds available
Trace Data | Lean mouse 1 | 1,057,022 reads (http://www.ncbi.nlm.nih.gov/Traces/trace.cgi?cmd=retrieve&val=ncbi_project_id%3D17391) available from the Trace Archive
Trace Data | Obese mouse 1 | 687,261 reads (http://www.ncbi.nlm.nih.gov/Traces/trace.cgi?cmd=retrieve&val=ncbi_project_id%3D17397) available from the Trace Archive
16S ribosomal RNA | Microbiota transplant donors and recipients | EF095962-EF100118 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=EF095962:EF100118%5baccn%5d)

A total of 54,991 high-quality sequence reads were obtained from three lean (+/+, ob/+) mice and two genetically obese (ob/ob) mice.

.

## Isolation Source

DNA was isolated from the distal gut (ceca) of eight-week old C57BL/6J ob/ob, ob/+, and +/+ mice using a bead beater to mechanically disrupt cells, followed by phenol-chloroform extraction. Mice were housed individually in microisolater cages where they were maintained in a specified pathogen-free state, under a 12h light cycle, and fed a standard polysaccharide-rich diet (Picolab, Purina) ad libitum.

## Genome Assembly

None

## Sequence Analysis

BLAST (http://www.ncbi.nlm.nih.gov/projects/genome/seq/BlastGen/BlastGen.cgi?pid=17391) against contigs from lean mouse 1.

BLAST (http://www.ncbi.nlm.nih.gov/projects/genome/seq/BlastGen/BlastGen.cgi?pid=17393) against contigs from lean mouse 2.

BLAST (http://www.ncbi.nlm.nih.gov/projects/genome/seq/BlastGen/BlastGen.cgi?pid=17395) against contigs from lean mouse 3.

BLAST (http://www.ncbi.nlm.nih.gov/projects/genome/seq/BlastGen/BlastGen.cgi?pid=17397) against contigs from obese mouse 1.

BLAST (http://www.ncbi.nlm.nih.gov/projects/genome/seq/BlastGen/BlastGen.cgi?pid=17399) against contigs from obese mouse 2.

BLAST (http://www.ncbi.nlm.nih.gov/projects/genome/seq/BlastGen/BlastGen.cgi?pid=17385) against contigs from combined lean and obese mice.

Genome Project ID: 17401 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?db=genomeprj&cmd=Retrieve&dopt=Overview&list_uids=17401)

## References

Turnbaugh PJ, Ley RE, Mahowald MA, Mabrini V, Mardis ER, Gordon JI. An obesity-associated gut microbiome with increased capacity for energy harvest. Nature. 2006 Dec 21;444(7122):1027-1031. 17183312