# Enhanced Biological Phosphorus Removal (EBPR) Sludge Community

Enhanced biological phosphorus removal (EBPR) is a treatment process in which microorganisms remove excessive inorganic phosphate from wastewater. However, the metabolic traits of this process are not well understood. Metagenomic analysis of two sludge samples allowed for the comparison of the microbial communities as well as the isolation of a near-complete genome of Acinetobacter phosphatis.

## Data

WGS study | EBPR sludge from Australia | AATN00000000
WGS study | EBPR sludge from USA | AATO00000000
Contigs | EBPR sludge from Australia | AATN01000001-AATN01011188 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AATN01000001:AATN01011188%5baccn%5d)
Contigs | EBPR sludge from USA | AATO01000001-AATO01015866 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AATO01000001:AATO01015866%5baccn%5d)
Scaffolds | No scaffolds available
Trace data | EBPR sludge from Australia | 96,563 reads (http://www.ncbi.nlm.nih.gov/Traces/trace.cgi?cmd=retrieve&val=ncbi_project_id%3D17659) available from the Trace Archive
Trace data | EBPR sludge from USA | 127,953 reads (http://www.ncbi.nlm.nih.gov/Traces/trace.cgi?cmd=retrieve&val=ncbi_project_id%3D17657) available from the Trace Archive
16S ribosomal RNA | No 16S rRNA sequences available

Approximately 98 and 78 Mbp of shotgun sequence data were obtained from the US and OZ (Australia) sludge, respectively.

## Isolation Source

Australia | Activated sludge from Thornside Sewage Treatment Plant in Queensland, Australia on August 18, 2004. The reactor was operated in four cycles of 6h per day, including 150 min anaerobic period, 180 min aerobic period, 30 min settling, and 5 min effluent withdrawing. The pH was kept at 7.0. The SBR was fed with propionate and a synthetic feed and nitrogen gas and air was bubbled through the liquid.
USA | Activated sludge mixed liquor from the Nine Springs Wastewater Treatment Plant in Madison, WI, USA on July 3, 2004. The reactor was operated in four cycles of 6h per day, including 130 min anaerobic phase, 190 min aerobic phase, 30 min settling, and 10 min effluent withdrawing. The pH was in the range of 7.0-7.3. The sequencing batch reactor (SBR) was fed with acetate, casamino acids, and a mineral salts medium with sodium phosphate. The SBR was operating for 11 months at the time of sampling.

## Genome Assembly

None

## Sequence Analysis

BLAST (http://www.ncbi.nlm.nih.gov/projects/genome/seq/BlastGen/BlastGen.cgi?pid=17657) against contigs from USA EBPR sludge.

BLAST (http://www.ncbi.nlm.nih.gov/projects/genome/seq/BlastGen/BlastGen.cgi?pid=17659) against contigs from Australian EBPR sludge.

Genome Project ID: 17663 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?db=genomeprj&cmd=Retrieve&dopt=Overview&list_uids=17663)

## References

Martin HG, Ivanova N, Kunin V, Warnecke F, Barry KW, McHardy AC, Yeates C, He S, Salamov AA, Szeto E, Dalin E, Putnam NH, Shapiro HJ, Pangilinan JL, Rigoutsos I, Kyrpides NC, Blackall LL, McMahon KD, Hugenholtz P. Metagenomic analysis of two enhanced biological phosphorus removal (EBPR) sludge communities. Nat Biotechnol. 2006 Oct;24(10):1263-1269. 16998472