# Mammuthus primigenius (Woolly Mammoth) Metagenome

Fossil DNA from preserved remains of woolly mammoth samples was isolated and compared to the genomes of different mammals in order to identify sequence reads derived from the woolly mammoth and to eliminate reads that were contamination. Comparisons to the African elephant (Loxodonta africana) support the paleontologically based divergence date of 5-6 million years.

## Data

WGS study | CAAM00000000
Contigs | CAAM02000001-CAAM02064265 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=CAAM02000001:CAAM02064265%5baccn%5d)
Scaffolds | No scaffolds available
Trace data | 366,957 reads (http://www.ncbi.nlm.nih.gov/Traces/trace.cgi?&cmd=retrieve&val=NCBI_PROJECT_ID%20%3D%2016317%20or%20NCBI_PROJECT_ID%20%3D%2017621&size=0&retrieve=Submit) available from the Trace Archive
16S ribosomal RNA | No 16S rRNA data available

Sequence reads were generated by 454 sequencing and queried to the elephant genome. Sequence reads whose best hits were against the elephant genome (or against the human genome to screen for human contaminants) were further analyzed. Only alignments greater then 30 nt were studied.

DQ188829 represents a complete mitochondrial genome derived from a mammoth bone (calibrated age between 11,900-13,400 years) found in Berelekh, Yakutia (71 deg N, 145 deg E) Russia.

EU153446, EU153448, EU153450, EU153451, EU153453, and EU155210 are additional complete mitochondrial genomes derived from mammoth.

## Isolation Source

Contributor | Isolation source | Notes
CCGB | Edentulous mandible remains (dated 27,740 +/- 220 ^14^C years) from the shore of Baikura-turku, a large bay on the southeastern side of Lake Taimyr in Siberia | 302,692 reads (http://www.ncbi.nlm.nih.gov/Traces/trace.cgi?&cmd=retrieve&val=NCBI_PROJECT_ID%20%3D%2016317&retrieve=Submit) averaging 95 bp and resulting in 28 million bp were isolated and submitted to the Trace Archive. 13 million bp (45.4%) of the sequencing reads were identified as mammoth DNA.
Max Planck Institute | 43,000 year old mammoth femur from Bol’shaya Kolopatkaya River (70 deg N, 151 deg E) in Russia | 64,265 reads (http://www.ncbi.nlm.nih.gov/Traces/trace.cgi?&cmd=retrieve&val=NCBI_PROJECT_ID%20%3D%2017621&retrieve=Submit) were submitted to the Trace Archive and included in project CAAM00000000

## Genome Assembly

None

## Sequence Analysis

BLAST (http://www.ncbi.nlm.nih.gov/projects/genome/seq/BlastGen/BlastGen.cgi?pid=17621) against these contigs.

Genome Project IDs: 16316 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?db=genomeprj&cmd=Retrieve&dopt=Overview&list_uids=16316)

## References

Poinar HN, Schwarz C, Qi J, Shapiro B, Macphee RD, Buiques B, Tikhonov A, Huson DH, Tomsho LP, Auch A, Rampp M, Miller W, Schuster SC. (2006). Metagenomics to paleogenomics: large-scale sequencing of mammoth DNA. Science.
Krause J, Dear PH, Pollack JL, Slatkin M, Spriggs H, Barnes I, Lister AM, Ebersberger I, Paabo S, Hofreiter M. (2006). Multiplex amplification of the mammoth mitochondrial genomes and the evolution of Elephantidae. Nature.
Stiller M, Green RE, Ronan M, Simons JF, Du L, He W, Egholm M, Rothberg JM, Keates SG, Ovodov ND, Antipina EE, Baryshnikov GF, Kuzmin YV, Vasilevski AA, Wuenschell GE, Termini J, Hofreiter M, Jaenicke-Despres V, Paabo S. (2006). Patterns of nucleotide misincorporations during enzymatic amplification and direct large-scale sequencing of ancient DNA. Proc Natl Acad Sci USA.
Briggs AW, Stenzel U, Johnson PL, Green RE, Kelso J, Prufer K, Meyer M, Krause J, Ronan MT, Lachmann M, Paabo S. (2007). Patterns of damage in genomic DNA sequences from a Neandertal. Proc Natl Acad Sci USA.