# Human Distal Gut Microbiome

A metagenomics approach was used to reveal microbial genomic and genetic diversity and to identify some of the distinctive functional attributes encoded in the human distal gut microbiome. Insight into the diversity within these samples was obtained by comparison of a subset of the shotgun reads to a completed bacterial genome. The analysis of the gene content and functional attributes of the gut microbiome in healthy humans defines them as superorganisms whose metabolism represents an amalgamation of microbial and human attributes.

## Data

WGS study | Human subject 7 | AAQK00000000
WGS study | Human subject 8 | AAQL00000000
Contigs | Human subject 7 | AAQK01000001-AAQK01010488 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AAQK01000001:AAQK01010488%5baccn%5d)
Contigs | Human subject 8 | AAQL01000001-AAQL01012020 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AAQL01000001:AAQL01012020%5baccn%5d)
Scaffolds | No scaffolds available
Trace data | 156,528 reads (http://www.ncbi.nlm.nih.gov/Traces/trace.cgi?cmd=retrieve&val=ncbi_project_id%3D16729) available from the Trace Archive
16S ribosomal RNA | Human subjects 7 and 8 | DQ325545-DQ327606 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=DQ325545:DQ327606%5baccn%5d)

A total of 74,462 high-quality sequence reads were obtained from two healthy humans. 17,668 contigs were assembled into 14,572 scaffolds, totaling 33 million bp. 40% of reads could not be assembled into contigs due to low depth of coverage (singletons). Coverage average depth in contigs: 2.13X

## Isolation Source

The human intestinal microbiota is composed of 10^13^ to 10^14^ microorganisms whose collective genome ("microbiome") contains at least 100 times as many genes as our own genome. 78 million base pairs of unique DNA sequence and 2062 polymerase chain reaction-amplified 16S ribosomal DNA sequences were obtained from the fecal DNAs of two healthy adults.

Subject 7 | Fecal specimen from 28 year old healthy female
Subject 8 | Fecal specimen from 37 year old healthy male

Both subjects had not used antibiotics of any other medications during the year before specimen collection.

## Genome Assembly

None

## Sequence Analysis

BLAST (http://www.ncbi.nlm.nih.gov/projects/genome/seq/BlastGen/BlastGen.cgi?pid=16729) against these contigs.

Genome Project ID: 16729 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?db=genomeprj&cmd=Retrieve&dopt=Overview&list_uids=16729)

## References

Gill SR, Pop M, Deboy RT, Eckburg PB, Turnbaugh PJ, Samuel BS, Gordon JI, Relman DA, Fraser-Liggett CM, Nelson KE. Metagenomic analysis of the human distal gut microbiome. Science. 2006 Jun 2;312(5778):1355-9.16741115
Microbial Genomics Home page at The Institute for Genomic Research (http://www.tigr.org/microbialGenomics.shtml)