# Human Fecal Virus

The enteric RNA viral community present in healthy humans has not been described, even though many RNA viruses are known to cause gastroenteritis. Using comparative metagenomic analysis, the RNA viruses found in three fecal samples from two healthy human individuals were analyzed. The vast majority were similar to a plant pathogenic RNA viruses, pepper mild mottle virus (PMMV), suggesting that humans may serve as vehicles for the dissemination of plant viruses.

## Data

WGS study | Sample 1 | AAMG00000000
WGS study | Sample 2 | AAMH00000000
WGS study | Sample 3 | AAMI00000000
Contigs | Sample 1 | AAMG01000001-AAMG01002373 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AAMG01000001:AAMG01002373%5baccn%5d)
Contigs | Sample 2 | AAMH01000001-AAMH01004593 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AAMH01000001:AAMH01004593%5baccn%5d)
Contigs | Sample 3 | AAMI01000001-AAMI01003329 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AAMI01000001:AAMI01003329%5baccn%5d)
Scaffolds | No scaffolds available
Trace data | 39,105 reads (http://www.ncbi.nlm.nih.gov/Traces/trace.cgi?cmd=retrieve&val=ncbi_project_id%3D16209) available from the Trace Archive
16S ribosomal RNA | No 16S rRNA data available

A total of 36,769 sequences were generated from all three samples. 25,779 (76.6%) were most similar to viruses, with 25,040 (97/1%) being homologous to plant viruses.

## Isolation Source

Three fecal samples from two healthy adults living in San Diego were used for virus isolation.

Sample 1 | Individual 1 fecal sample
Sample 2 | Individual 1 fecal sample collected 6 months after collecting Sample 1
Sample 3 | Individual 2 fecal sample

Feces-borne viral particles were concentrated and treated with DNase and RNase to eliminate potential contamination with nucleic acids.

## Genome Assembly

None

## Sequence Analysis

BLAST (http://www.ncbi.nlm.nih.gov/projects/genome/seq/BlastGen/BlastGen.cgi?pid=16209) against these contigs.

Genome Project ID: 16209 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?db=genomeprj&cmd=Retrieve&dopt=Overview&list_uids=16209)

## References

Zhang T, Breitbart M, Lee WH, Run JQ, Wei CL, Soh SW, Hibberd ML, Liu ET, Rohwer F, Ruan Y. RNA viral community in human feces: prevalence of plant pathogenic viruses. PLoS Biol. 2006 Jan;4(1):e3. 16336043
More information about the Human Fecal Virus project is available at the Genome Institute of Singapore (http://giscompute.gis.a-star.edu.sg/~charlie/cgi-bin/Website/index.html).