# Mediterranean Gutless Worm Metagenome

Olavius algarvensis is a marine worm that belongs to a group of oligochaetes that lack a mouth, gut, anus and nephridia (kidney-like organs). These worms live in obligate and species-specific associations with multiple extracellular bacterial endosymbionts that are located just below the worm cuticle. A metagenomic approach was used to isolate four co-occurring bacterial symbionts. These symbionts were taxonomically identified and shown to be capable of carbon fixation, which provides the host with multiple sources of nutrition

## Data

WGS study | AASZ00000000
Contigs | AASZ01000001-AASZ01005597 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=AASZ01000001:AASZ01005597%5baccn%5d)
Scaffolds | DS021107-DS021197 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=DS021107:DS021197%5baccn%5d)
Scaffolds | DS021198-DS021219 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=DS021198:DS021219%5baccn%5d)
Scaffolds | DS021220-DS021445 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=DS021220:DS021445%5baccn%5d)
Scaffolds | DS021446-DS021617 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=DS021446:DS021617%5baccn%5d)
Scaffolds | DS021618-DS022223 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=DS021618:DS022223%5baccn%5d)
Trace data | 313,773 reads (http://www.ncbi.nlm.nih.gov/Traces/trace.cgi?cmd=retrieve&val=ncbi_project_id%3D17779) available from the Trace Archive
16S ribosomal RNA | No 16S rRNA data available

Approximately 60 ug of metagenomic DNA was purified per 200 frozen specimens. 185 million bases of 3 kb library end sequence and 19 Mb of fosmid end sequence was generated for a total of 204 Mb of high-quality shotgun sequence data. These metagenomic shotgun libraries contained a total of 281,448 trimmed sequence reads. 61% of the reads were assembled into a filtered set containing 2,286 scaffolds with 39 Mb of sequence, of which 40% was gap. Binning of the Olavius spp. symbionts’ metagenome results in 511 scaffolds forming four distinct clusters.

## Isolation Source

Juvenile and adult specimens of the marine oligochaetes Olavius algarvenis and Olavius ilvae (co-occurring gutless oligochaete species) were collected in May and September 2004 from 5.6 m water depth in silicate sediments around sea grass beds in a bay off Capo di Sant’ Andrea, Elba, Italy (42 deg 48’ 26’’ N, 010 deg 08’ 28’’ E). Samples were enriched for bacterial cells from approximately 200 live worms.

## Genome Assembly

Binning of the 2,286 scaffolds was based on GC-content, dinucleotide relative abundance, Markov model-based statistical evaluation of tri-, tetra and pentamer over- and under representation, and normalized chaos game representations for tri- to hexamers Deschavanne. This resulted in 511 scaffolds distributed into four distinct clusters, identified based on 16S ribosomal RNA genes and phylogenetic analysis of predicted proteins within each cluster of scaffolds.

Assembly | Sequences | Notes
Olavius algarvensis Gamma 1 endosymbiont | DS021107-DS021197 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=DS021107:DS021197%5baccn%5d) | Contains genes required for autotrophic CO2 fixation, reduced sulphur oxidation and globule storage
Olavius algarvensis Gamma 3 endosymbiont | DS021198-DS021219 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=DS021198:DS021219%5baccn%5d) | Sulphur-oxidizing chemoautotroph
Olavius algarvensis Delta 1 endosymbiont | DS021220-DS021445 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=DS021220:DS021445%5baccn%5d) | Contains genes coding for the transport and utilization of a variety of carbohydrate substrates
Olavius algarvensis Delta 4 endosymbiont | DS021446-DS021617 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=DS021446:DS021617%5baccn%5d) | Reduces sulphur compounds of intermediate oxidation states
symbiont metagenome | DS021618-DS022223 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?holding=&db=Nucleotide&cmd=search&term=DS021618:DS022223%5baccn%5d) | Possibly derived from endosymbionts of Olavius ilvae and/or other “contaminating” species

## Sequence Analysis

BLAST (http://www.ncbi.nlm.nih.gov/projects/genome/seq/BlastGen/BlastGen.cgi?pid=17779) against these contigs.

Genome Project IDs: 17779 (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?db=genomeprj&cmd=Retrieve&dopt=Overview&list_uids=17779)

## References

Woyke T, Teeling H, Inanova NN, Huntemann M, Richter M, Gloeckner FO, Boffelli D, Anderson IJ, Barry KW, Shapiro HJ, Szeto E, Kyrpides NC, Mussmann M, Amann R, Bergin C, Ruehland C, Rubin EM, Dubilier N. Symbiosis insights through metagenomic analysis of a microbial consortium. Nature. 2006 Oct 26;443(7114):950-5.