# STATISTICAL BRIEF #544 Trends in the Number and Percentage of the Population with Any Dental or Medical Visits, 2019

Highlights

▪ In 2019, about 37 percent of Americans (120.6 million in 2019) had at least one medical and one dental visit, and 9 percent (29.5 million in 2019) had least one dental visit and no medical visit.
▪ The percentage of Americans visiting both a medical and dental provider in 2019 was higher among those who had private insurance with dental coverage (47.2 percent) compared to those who had private insurance without dental coverage (22.8 percent) or were publicly covered (29.8 percent).
▪ Overall, the proportion of publicly insured individuals who had contact with a medical provider (46.1 percent) was the same as for privately insured individuals without dental insurance (46.2 percent). However, their likelihood of having both dental and medical visits (29.8 percent) was higher than for privately insured individuals without dental insurance (22.8 percent).
▪ Among persons with public coverage, the percentage with medical and dental visits in 2019 was higher among non-Hispanic White individuals (35.1 percent) compared with those who are Hispanic (24.8 percent) and non-Hispanic Black (23.1 percent).
▪ Overall, regardless of insurance status, the percentage of individuals with both medical and dental visits in 2019 was higher among persons who are non-Hispanic White (43.3 percent) compared with those who are Hispanic (25.3 percent) and non-Hispanic Black (26.4 percent).

## Introduction

In 2000, the first Surgeon General’s Report on oral health was released. Oral Health in America provided numerous examples of the connection between oral health and overall health, concluding that “oral health means much more than healthy teeth” and “is essential to the general health and wellbeing of all Americans. (1) Since that report’s publication, there has been a concerted effort for better integration between oral health and overall health across the country.

In 2021, the National Institutes of Health released a follow-up report titled Oral Health in America: Advances and Challenges highlighting the disparities that continued to exist in dental disease burden and access to oral healthcare. (2) In addition, the report focused on the advantages of integrating oral health into overall healthcare and identified implementation challenges and opportunities in this effort. As noted in the report, “commercial health systems and insurers have tested new models of integrated care delivery, with the purpose of improving patient outcomes while reducing cost. An important goal of integration and workforce expansion is to encourage dental team members to work at the top of their collective scope of licensing capabilities in order to maximize access to dental care.”

This integration also has the potential to improve the overall efficiency of healthcare delivery in the United States. For example, the Health Policy Institute of the American Dental Association, the nation’s dental professional organization, estimated that healthcare costs in the United States could be reduced by more than $100 million each year through screening for chronic diseases in dental offices. (3)

To provide a foundation for examining the integration of oral health into overall healthcare and the health equity implications, this brief provides estimates of the number of persons with any dental or medical visits in the year by various individual characteristics, including insurance status, using 2019 data from the Medical Expenditure Panel Survey Household Component (MEPS-HC). This analysis complements Statistical Brief #537, which examined the number and percentage of persons with dental and medical visits using 2003 to 2018 data. In this brief, we provide total annual estimates for 2019 and further examine dental and medical visits by insurance coverage, age, sex, race/ethnicity, and census region. Using 2017–2019 data from the MEPS-HC, we also provide regional and some state estimates of the percent of persons with dental and medical visits.

A dental-only visit included any reported visit in the year to any type of dental provider, including general dentists, specialists, hygienists, and technicians. A medical-only visit included any reported visit in the year to any physician or nonphysician provider in an office-based, inpatient, outpatient, emergency room, or home health setting. All differences between estimates discussed in the text are statistically significant at the 0.05 level or better unless otherwise noted.

## Findings

### U.S. medical and dental visits by insurance category (tables 1 and 2)

Table 1 shows the number and percent of persons for a reporting year visiting both a medical provider and a dental provider (medical and dental), medical provider and not a dental provider (medical-only), dental provider and not a medical provider (dental-only), or neither a medical provider or a dental provider (neither) by insurance coverage and demographic category for 2019. Overall, private medical and dental insurance coverage across demographic stratification was associated with higher rates of dental-only and medical and dental visits. Generally, publicly insured individuals have greater use of medical and dental visits than privately insured individuals without dental coverage. Publicly insured individuals have rates of medical-only visits that are similar to those of privately insured individuals without dental coverage.

About 37 percent of individuals had both a medical and a dental visit in 2019, while 33 percent had a medical-only visit and 9 percent had a dental-only visit. While 47 percent of individuals with private medical and dental insurance had a medical and a dental visit, 33 percent of those with private medical without dental insurance had a medical and a dental visit. About 30 percent of individuals with public coverage had a medical and a dental visit. About 9 percent of all the population had a dental-only visit. Sixty-three percent of those who were uninsured did not have a medical or a dental visit.

In general, research has shown that women are overall more likely to use health services than men; our analysis confirms these findings with respect to dental and medical visits. (4) Women with private medical and dental insurance were more likely than men in that category to have both a medical and a dental visit (51.7 percent compared to 42.5 percent), and less likely to have neither a medical nor a dental visit (12.8 percent compared to 19.3 percent). For publicly insured women and men, these gender differences are smaller: 30.6 percent compared to 28.8 percent, and 16.2 percent compared to 21.2 percent, respectively.

There were significant differences in the patterns of healthcare utilization based on age as well. Among individuals with private medical and dental insurance, older persons (over 65 years) were most likely to have both a medical and a dental visit (75.8 percent) and least likely to have neither a medical nor a dental visit (3.2 percent) compared with other age groups. In contrast, publicly covered seniors were less likely than those with private insurance to have both a medical and a dental visit (37.6 percent) and more likely to have neither a medical nor a dental visit (8.7 percent).

Among children and adolescents ages 6–17, those with private medical and dental insurance were the most likely to have a medical and a dental visit (54.7 percent). In contrast, only 38.4 percent of their publicly insured counterparts had a medical and a dental visit. Interestingly, in this age group, insurance coverage had only a small impact on the dental-only visit rates, with an overall rate of 15.4 percent that ranged between 13.2 percent and 19 percent over the four categories of insurance.

Among individuals with private medical and dental insurance, Non-Hispanic Whites were more likely to have a medical and a dental visit than non-Hispanic Blacks (52.0 percent vs. 35.8 percent) or Hispanics (52.0 percent vs. 36.4 percent). These racial disparities persisted for publicly insured individuals but were smaller, reflecting the role of public coverage in reducing health disparities. The rates for having both types of visits among those with public insurance only were 35.1 percent vs. 23.1 percent for non-Hispanic Whites vs. non-Hispanic Blacks and 35.1 percent vs. 24.8 percent for non-Hispanic Whites vs. Hispanics.

Finally, across all insurance categories and census regions, individuals with private medical and dental insurance living in the West were most likely to have a dental-only visit in 2019. Overall, those living in the South and West were less likely to have both medical and dental visits compared to those living in the other two census regions.

Table 2 shows the number and percent of persons with medical and dental, medical-only, and dental-only visits by insurance coverage and geographic area from 2017 to 2019.

Among individuals with private medical and dental insurance, residents of Massachusetts had the highest proportion of medical and dental visits (60.1 percent), while persons living in Texas had the lowest proportion of medical and dental visits (37.1 percent). For uninsured persons, residents of Colorado had the highest proportion of dental-only visits (18.3 percent). Among persons with public coverage only, persons living in Minnesota had the highest rate for dental-only visits (10.1 percent). For persons with private medical insurance and no dental, residents of Indiana had the highest proportion of dental-only visits (9.0 percent), and persons in Alabama and Kentucky had the lowest proportion of dental-only visits (less than 1.0 percent).^1^ Virginia was the state with the highest proportion of persons who had a medical-only visit among those with only public coverage (57.8 percent).

Finally, across all states and insurance categories, the highest proportion of individuals with neither a medical nor a dental visit were uninsured persons living in California (70.7 percent). The lowest proportion of individuals with neither a medical nor a dental visit was persons with private medical and dental coverage in Massachusetts (9.5 percent).

## Data Source

This statistical brief uses data from the following public use data files:

Data Files | 2017 | 2018 | 2019
Full-Year Consolidated | HC-201 | HC-209 | HC-216
Dental events | HC-197B | HC-206B | HC-213B
Inpatient events | HC-197D | HC-206D | HC-213D
Emergency room events | HC-197E | HC-206E | HC-213E
Outpatient events | HC-197F | HC-206F | HC-213F
Office-based events | HC-197G | HC-206G | HC-213G
Home health events | HC-197H | HC-206H | HC-213H

Note: Total annual estimates are provided for 2019. State-level estimates include data from 2017 to 2019 to assure sufficient sample sizes.

## Definitions

### Dental-only visits

A dental-only visit is an in-person visit to any type of dental provider, including general dentists and specialists such as periodontists and non-dentists such as hygienists and technicians.

### Medical-only visits

A medical-only visit is an in-person visit to any type of medical provider, including physicians (medical doctors) and nonphysicians (e.g., nurses, technicians) in an office-based, inpatient, outpatient, emergency room, or home health setting.

### Insurance Coverage

The categories of insurance coverage were defined hierarchically based on the following scheme: Respondents reporting 1 or more months of private insurance coverage were classified as “Some private with dental” or “Some private without dental,” depending on whether the private insurance reported included dental coverage. Persons reporting 0 months of private insurance but 1 or more months of Medicare, Medicaid, or some other public coverage such as TRICARE were classified as “Some public no private.” Finally, persons reporting 0 months of insurance coverage of any kind were classified as “Uninsured.”

### Race/ethnicity

Classification by race/ethnicity was based on information reported for each family member. First, respondents were asked if the person's main national origin or ancestry was Puerto Rican; Cuban; Mexican, Mexican American, or Chicano; other Latin American; or other Spanish. All persons whose main national origin or ancestry was reported in one of these Hispanic groups, regardless of racial background, were classified as Hispanic. All other persons were classified according to their reported race. For this analysis, the following classification by race and ethnicity was used: Hispanic, non-Hispanic Black, non-Hispanic White, and non-Hispanic other. The Other category includes American Indian, Alaska Native, Asian or Pacific Islander, other race, and multiple races.

### Age

The age variable is based on the sample person's age as of the end of the year. If data were not collected during a round because the sample person was out of scope (e.g., deceased or institutionalized), then age at the time of the previous round was used.

### State estimates

Estimates for states were produced using a special set of MEPS sampling weights that were stratified to state population control totals by demographic characteristics. Three years of MEPS data were pooled to meet sufficient sample sizes for the estimates in this brief.

### Census region

The census region variable is based on the location of the household at the end of the year. If missing, the most recent location available is used.

Region | Included States
Northeast | Connecticut, Maine, Massachusetts, New Hampshire, New Jersey, New York, Pennsylvania, Rhode Island, and Vermont
Midwest | Illinois, Indiana, Iowa, Kansas, Michigan, Minnesota, Missouri, Nebraska, North Dakota, Ohio, South Dakota, and Wisconsin
South | Alabama, Arkansas, Delaware, District of Columbia, Florida, Georgia, Kentucky, Louisiana, Maryland, Mississippi, North Carolina, Oklahoma, South Carolina, Tennessee, Texas, Virginia, West Virginia
West | Alaska, Arizona, California, Colorado, Hawaii, Idaho, Montana, Nevada, New Mexico, Oregon, Utah, Washington, and Wyoming

## About MEPS

The MEPS-HC collects nationally representative data on healthcare use, expenditures, sources of payment, and insurance coverage for the U.S. civilian noninstitutionalized population. MEPS-HC is cosponsored by the Agency for Healthcare Research and Quality (AHRQ) and the National Center for Health Statistics. More information about the MEPS-HC can be found on the MEPS website at http://www.meps.ahrq.gov.

## References

1 U.S. Department of Health and Human Services. Oral Health in America: A Report of the Surgeon General. Rockville, MD: U.S. Department of Health and Human Services, National Institutes of Health, National Institute of Dental and Craniofacial Research; 2000.
2 U.S. Department of Health and Human Services. Oral Health in America: Advances and Challenges. Rockville, MD: U.S. Department of Health and Human Services, National Institutes of Health, National Institute of Dental and Craniofacial Research; 2001.
3 American Dental Association, Health Policy Institute. Screening for Chronic Diseases in the Dental Office. 2018. https://legacy.ada.org/~/media/ADA/Science%20and%20Research/HPI/Files/ADA_HPI_DentalOfcScreening.pdf?la=en
4 National Academies of Sciences, Engineering, and Medicine; Health and Medicine Division; Board on Health Care Services; Committee on Health Care Utilization and Adults with Disabilities. Health-Care Utilization as a Proxy in Disability Determination; 2, Factors that affect health-care utilization. Washington, DC: National Academies Press; March 2018. https://www.ncbi.nlm.nih.gov/books/NBK500097.

1 Specifically, the rate reported for dental-only visits among persons with private medical and no dental coverage was 0.0% in Alabama and 0.9% in Kentucky. Due to sample size constraints, MEPS is not able to produce reliable estimates for all population subgroups in all states.

Table 1 Number and percent of persons with medical and dental visits by insurance category by demographic category, MEPS 2019

Visit Types | | | | Dental and medical visits | Dental visits only | Medical visits only | Neither visit
Domain | Level | Insurance category | Population (1,000s) | Percent (SE) | Percent (SE) | Percent (SE) | Percent (SE)
Overall | Overall | Overall | 327,397 | 36.8 (0.5) | 9.0 (0.3) | 33.4 (0.4) | 20.8 (0.4)
| | Private medical with dental | 177,684 | 47.2 (0.6) | 11.7 (0.4) | 25.1 (0.5) | 16.0 (0.5)
| | Private medical without dental | 45,259 | 22.8 (1.0) | 5.0 (0.5) | 46.2 (1.1) | 26.0 (1.0)
| | Public only | 85,125 | 29.8 (0.7) | 5.7 (0.3) | 46.1 (0.6) | 18.5 (0.7)
| | Uninsured | 19,329 | 5.9 (0.6) | 7.8 (0.8) | 22.9 (1.3) | 63.4 (1.6)
Sex | Male | Overall | 160,438 | 33.1 (0.6) | 9.7 (0.3) | 32.2 (0.5) | 25.0 (0.6)
| | Private medical with dental | 87,045 | 42.5 (0.8) | 12.8 (0.5) | 25.4 (0.7) | 19.3 (0.6)
| | Private medical without dental | 22,692 | 19.3 (1.2) | 5.3 (0.7) | 43.4 (1.5) | 32.0 (1.4)
| | Public only | 38,940 | 28.8 (0.9) | 5.6 (0.5) | 44.4 (0.9) | 21.2 (1.0)
| | Uninsured | 11,761 | 4.9 (0.8) | 8.0 (1.1) | 20.7 (1.5) | 66.4 (1.9)
| Female | Overall | 166,958 | 40.4 (0.7) | 8.4 (0.3) | 34.4 (0.5) | 16.8 (0.5)
| | Private medical with dental | 90,639 | 51.7 (0.9) | 10.7 (0.5) | 24.9 (0.7) | 12.8 (0.5)
| | Private medical without dental | 22,566 | 26.3 (1.2) | 4.8 (0.6) | 49.0 (1.4) | 20.0 (1.2)
| | Public only | 46,185 | 30.6 (0.8) | 5.7 (0.4) | 47.5 (0.8) | 16.2 (0.7)
| | Uninsured | 7,568 | 7.6 (1.1) | 7.5 (1.1) | 26.2 (1.8) | 58.7 (2.1)
Age | 0–5 | Overall | 23,780 | 28.7 (1.3) | 5.0 (0.6) | 54.7 (1.4) | 11.6 (0.9)
| | Private medical with dental | 11,326 | 36.0 (2.0) | 5.8 (1.0) | 49.7 (2.0) | 8.5 (1.3)
| | Private medical without dental | 3,077 | 12.3 (3.4) | 2.9 (1.4)^*^ | 74.4 (4.2) | 10.4 (2.3)
| | Public only | 9,030 | 25.7 (1.9) | 4.2 (0.7) | 55.4 (2.1) | 14.7 (1.7)
| | Uninsured | 347 | --- | --- | --- | ---
| 6–17 | Overall | 50,068 | 45.3 (1.2) | 15.4 (0.8) | 21.0 (0.8) | 18.3 (0.8)
| | Private medical with dental | 27,069 | 54.7 (1.6) | 16.7 (1.1) | 15.9 (1.1) | 12.7 (1.1)
| | Private medical without dental | 3,761 | 22.4 (3.1) | 13.2 (2.6) | 36.4 (3.8) | 28.0 (3.2)
| | Public only | 18,147 | 38.4 (1.9) | 13.8 (1.2) | 25.1 (1.4) | 22.6 (1.5)
| | Uninsured | 1,091 | 8.5 (3.0)^*^ | 19.0 (5.3) | 22.1 (4.9) | 50.4 (6.1)
| 18–64 | Overall | 198,788 | 32.0 (0.6) | 9.7 (0.3) | 31.9 (0.5) | 26.4 (0.6)
| | Private medical with dental | 122,026 | 42.5 (0.7) | 12.3 (0.4) | 26.0 (0.6) | 19.2 (0.5)
| | Private medical without dental | 26,982 | 16.2 (1.1) | 5.5 (0.7) | 42.6 (1.4) | 35.7 (1.3)
| | Public only | 32,066 | 19.8 (0.9) | 5.0 (0.5) | 50.2 (1.0) | 25.1 (1.0)
| | Uninsured | 17,713 | 5.6 (0.7) | 6.9 (0.8) | 22.8 (1.3) | 64.7 (1.5)
| 65+ | Overall | 54,761 | 50.3 (0.9) | 2.2 (0.2) | 40.8 (0.9) | 6.7 (0.4)
| | Private medical with dental | 17,263 | 75.8 (1.3) | 3.9 (0.5) | 17.2 (1.1) | 3.2 (0.5)
| | Private medical without dental | 11,438 | 41.1 (1.8) | 1.8 (0.4) | 50.3 (1.7) | 6.8 (1.0)
| | Public only | 25,881 | 37.6 (1.2) | 1.3 (0.2) | 52.5 (1.2) | 8.7 (0.6)
| | Uninsured | 178 | --- | --- | --- | ---
Race/ethnicity | Hispanic | Overall | 60,457 | 25.3 (0.9) | 8.8 (0.5) | 33.4 (0.8) | 32.5 (1.0)
| | Private medical with dental | 23,410 | 36.4 (1.5) | 12.1 (1.0) | 27.3 (1.5) | 24.2 (1.1)
| | Private medical without dental | 6,190 | 14.8 (1.9) | 5.3 (1.2) | 44.8 (2.4) | 35.1 (2.6)
| | Public only | 21,911 | 24.8 (1.4) | 7.5 (0.8) | 41.5 (1.3) | 26.2 (1.5)
| | Uninsured | 8,945 | 4.6 (0.7) | 5.6 (0.9) | 21.5 (1.9) | 68.2 (1.8)
| Non-Hispanic White | Overall | 195,489 | 43.3 (0.7) | 9.2 (0.3) | 32.1 (0.5) | 15.5 (0.5)
| | Private medical with dental | 117,292 | 52.0 (0.9) | 11.7 (0.5) | 23.2 (0.6) | 13.0 (0.6)
| | Private medical without dental | 30,991 | 27.8 (1.4) | 5.7 (0.6) | 45.8 (1.4) | 20.7 (1.2)
| | Public only | 40,991 | 35.1 (1.1) | 4.2 (0.5) | 48.2 (1.0) | 12.5 (0.8)
| | Uninsured | 6,214 | 9.4 (1.5) | 10.4 (1.5) | 24.4 (2.3) | 55.8 (2.8)
| Non-Hispanic Black | Overall | 40,181 | 26.4 (1.1) | 7.5 (0.6) | 38.9 (1.1) | 27.2 (1.0)
| | Private medical with dental | 19,287 | 35.8 (1.8) | 9.9 (1.0) | 31.4 (1.7) | 22.9 (1.5)
| | Private medical without dental | 4,132 | 8.7 (1.9) | 1.7 (0.7)^*^ | 49.7 (3.3) | 39.9 (3.5)
| | Public only | 14,071 | 23.1 (1.4) | 6.1 (0.7) | 48.7 (1.5) | 22.1 (1.3)
| | Uninsured | 2,691 | 2.9 (1.4)^*^ | 6.7 (2.4)^*^ | 24.8 (3.1) | 65.5 (4.1)
| Other | Overall | 31,270 | 32.3 (1.4) | 10.5 (0.9) | 34.1 (1.3) | 23.2 (1.3)
| | Private medical with dental | 17,695 | 41.4 (1.8) | 13.4 (1.2) | 28.2 (1.9) | 17.0 (1.5)
| | Private medical without dental | 3,946 | 10.6 (2.1) | 2.6 (1.1)^*^ | 47.7 (3.2) | 39.2 (3.2)
| | Public only | 8,151 | 27.9 (2.7) | 7.5 (1.2) | 42.8 (2.4) | 21.8 (2.4)
| | Uninsured | 1,479 | 4.7 (2.7)^*^ | 12.5 (5.4)^*^ | 21.0 (4.9) | 61.8 (6.5)
Census region | Northeast | Overall | 55,930 | 40.3 (1.1) | 8.0 (0.6) | 31.9 (0.7) | 19.8 (1.0)
| | Private medical with dental | 31,455 | 49.5 (1.4) | 10.5 (0.9) | 23.4 (1.0) | 16.7 (1.4)
| | Private medical without dental | 6,965 | 29.1 (2.7) | 4.0 (0.9) | 44.0 (2.6) | 22.9 (3.1)
| | Public only | 15,726 | 30.7 (1.6) | 5.3 (0.8) | 45.2 (1.3) | 18.7 (1.6)
| | Uninsured | 1,784 | 7.6 (2.5)^*^ | 4.4 (1.8)^*^ | 17.1 (4.7) | 71.0 (5.6)
| Midwest | Overall | 68,393 | 39.4 (1.0) | 9.4 (0.6) | 34.8 (0.8) | 16.4 (0.7)
| | Private medical with dental | 39,575 | 49.7 (1.0) | 11.8 (0.8) | 26.2 (1.0) | 12.3 (0.7)
| | Private medical without dental | 10,232 | 22.3 (2.5) | 6.1 (1.2) | 48.1 (2.5) | 23.5 (2.0)
| | Public only | 15,761 | 29.6 (1.5) | 5.5 (0.6) | 49.9 (1.2) | 15.0 (1.3)
| | Uninsured | 2,826 | 10.7 (2.2) | 10.6 (2.3) | 24.4 (2.7) | 54.3 (4.1)
| South | Overall | 124,766 | 33.9 (1.0) | 7.9 (0.4) | 34.9 (0.6) | 23.3 (0.9)
| | Private medical with dental | 64,252 | 45.4 (1.4) | 10.5 (0.6) | 26.6 (0.9) | 17.5 (0.9)
| | Private medical without dental | 18,343 | 19.7 (1.4) | 4.3 (0.7) | 47.0 (1.7) | 29.1 (1.7)
| | Public only | 31,323 | 28.8 (1.2) | 4.7 (0.5) | 48.2 (1.1) | 18.2 (1.1)
| | Uninsured | 10,848 | 4.5 (0.8) | 7.6 (1.2) | 24.7 (1.7) | 63.2 (2.2)
| West | Overall | 78,307 | 36.8 (0.9) | 11.1 (0.6) | 30.7 (0.8) | 21.4 (0.8)
| | Private medical with dental | 42,402 | 45.7 (1.2) | 14.6 (0.8) | 23.3 (1.1) | 16.5 (0.9)
| | Private medical without dental | 9,719 | 24.6 (1.7) | 6.2 (1.1) | 44.2 (2.6) | 25.0 (1.9)
| | Public only | 22,315 | 30.7 (1.6) | 7.3 (0.8) | 40.9 (1.3) | 21.1 (1.4)
| | Uninsured | 3,871 | 5.8 (1.2) | 8.1 (1.6) | 19.2 (2.8) | 66.9 (2.7)

* Standard errors for estimates appear in parentheses.

--- Estimate suppressed due to small sample size.

* Estimate has high relative standard error.

Dental includes any visit to any type of dental provider.

Medical includes any visit to any office-based, outpatient, inpatient, emergency room, or home health provider.

Source: Agency for Healthcare Research and Quality, Center for Financing, Access and Cost Trends, MEPS-HC, 2018–2019.

Table 2 Number and percent of persons with medical and dental visits by insurance category by geographic area, MEPS 2017–2019

| | | | Dental and medical visits | Dental visits only | Medical visits only | Neither visit
Domain | Level | Insurance category | Population (1,000s) | Percent (SE) | Percent (SE) | Percent (SE) | Percent (SE)
New England | MA | Overall | 6,898 | 51.5 (1.8) | 8.9 (0.9) | 27.5 (1.4) | 12.1 (0.7)
| | Private medical with dental | 4,326 | 60.1 (2.1) | 11.5 (0.8) | 18.9 (0.9) | 9.5 (0.9)
| | Private medical without dental | 793 | 37.3 (2.8) | 3.9 (1.9)^*^ | 42.2 (5.6) | 16.6 (4.0)
| | Public only | 1,734 | 37.7 (1.9) | 5.0 (1.7)^*^ | 42.8 (1.6) | 14.6 (1.1)
| | Uninsured | 45 | --- | --- | --- | ---
Middle Atlantic | NJ | Overall | 8,943 | 37.3 (3.1) | 7.9 (0.6) | 36.4 (2.1) | 18.4 (0.6)
| | Private medical with dental | 5,489 | 43.5 (4.3) | 10.9 (1.1) | 30.9 (4.1) | 14.7 (1.1)
| | Private medical without dental | 1,005 | 20.3 (5.3) | 1.4 (1.0)^*^ | 49.6 (4.4) | 28.7 (2.9)
| | Public only | 2,005 | 34.9 (2.4) | 3.2 (1.0)^*^ | 48.9 (1.9) | 13.0 (1.6)
| | Uninsured | 443 | 9.7 (2.9) | 7.7 (3.3)^*^ | 17.6 (8.4)^*^ | 65.0 (13.5)
| NY | Overall | 19,584 | 36.0 (1.0) | 6.6 (0.4) | 35.8 (0.7) | 21.7 (1.2)
| | Private medical with dental | 10,311 | 45.6 (1.5) | 8.9 (0.8) | 27.6 (1.2) | 17.8 (1.3)
| | Private medical without dental | 2,895 | 24.2 (1.4) | 2.0 (0.6)^*^ | 47.1 (2.3) | 26.7 (2.2)
| | Public only | 5,826 | 27.9 (1.1) | 4.7 (0.6) | 45.9 (1.7) | 21.6 (2.0)
| | Uninsured | 552 | 4.4 (1.5)^*^ | 6.3 (2.6)^*^ | 21.8 (4.3) | 67.4 (5.5)
| PA | Overall | 12,704 | 40.8 (0.8) | 8.9 (0.4) | 33.5 (0.8) | 16.8 (0.5)
| | Private medical with dental | 7,492 | 47.3 (0.8) | 11.9 (0.6) | 26.1 (0.9) | 14.7 (0.8)
| | Private medical without dental | 1,696 | 30.6 (2.3) | 4.7 (0.8) | 44.5 (2.1) | 20.2 (2.7)
| | Public only | 3,122 | 34.9 (2.5) | 3.8 (0.9) | 46.6 (1.7) | 14.7 (1.3)
| | Uninsured | 394 | 9.1 (3.7)^*^ | 10.4 (2.3) | 22.0 (5.1) | 58.5 (7.1)
East North Central | IL | Overall | 12,653 | 38.0 (1.7) | 9.0 (0.7) | 35.1 (1.9) | 17.9 (1.2)
| | Private medical with dental | 7,310 | 47.0 (1.5) | 11.3 (1.0) | 28.0 (1.4) | 13.8 (1.2)
| | Private medical without dental | 2,017 | 26.8 (3.8) | 5.5 (1.3) | 45.3 (3.8) | 22.3 (1.2)
| | Public only | 2,798 | 27.1 (3.1) | 4.7 (0.7) | 47.7 (3.3) | 20.5 (2.0)
| | Uninsured | 527 | 13.7 (5.4)^*^ | 14.7 (3.5) | 27.5 (1.8) | 44.1 (7.7)
| IN | Overall | 6,694 | 34.3 (2.2) | 9.0 (1.8) | 35.2 (0.8) | 21.5 (0.7)
| | Private medical with dental | 3,827 | 41.8 (3.2) | 10.0 (2.4) | 30.5 (1.4) | 17.7 (1.0)
| | Private medical without dental | 1,158 | 19.1 (2.9) | 9.0 (2.3) | 42.1 (4.4) | 29.9 (4.9)
| | Public only | 1,378 | 31.0 (3.3) | 5.4 (0.9) | 47.9 (1.5) | 15.7 (2.4)
| | Uninsured | 332 | 15.9 (3.9) | 11.8 (3.0) | 12.5 (3.3) | 59.8 (7.8)
| MI | Overall | 10,002 | 44.3 (1.1) | 9.2 (0.6) | 32.0 (0.7) | 14.6 (1.0)
| | Private medical with dental | 6,354 | 54.0 (1.1) | 11.4 (0.9) | 23.5 (1.0) | 11.1 (1.1)
| | Private medical without dental | 1,115 | 26.1 (3.0) | 6.8 (1.0) | 45.0 (2.2) | 22.1 (2.2)
| | Public only | 2,233 | 30.6 (1.2) | 3.6 (0.6) | 49.5 (2.1) | 16.2 (1.5)
| | Uninsured | 299 | 7.2 (3.3)^*^ | 11.0 (4.8)^*^ | 32.4 (8.6) | 49.4 (6.0)
| OH | Overall | 11,708 | 38.7 (1.4) | 6.5 (0.6) | 38.3 (1.0) | 16.5 (0.8)
| | Private medical with dental | 6,516 | 48.4 (2.4) | 8.8 (0.6) | 30.7 (1.9) | 12.1 (0.9)
| | Private medical without dental | 1,523 | 24.0 (3.9) | 3.5 (1.3)^*^ | 48.8 (4.5) | 23.7 (2.5)
| | Public only | 3,142 | 30.4 (2.3) | 3.2 (0.5) | 49.0 (1.7) | 17.5 (1.1)
| | Uninsured | 527 | 11.7 (5.2)^*^ | 6.3 (4.3)^*^ | 37.4 (6.0) | 44.6 (4.1)
| WI | Overall | 5,852 | 42.5 (2.0) | 11.0 (1.1) | 29.4 (1.5) | 17.1 (0.6)
| | Private medical with dental | 3,382 | 51.9 (1.9) | 14.5 (1.8) | 20.9 (1.4) | 12.7 (1.9)
| | Private medical without dental | 1,096 | 27.8 (2.8) | 6.4 (0.7) | 40.6 (2.5) | 25.1 (2.6)
| | Public only | 1,163 | 33.9 (3.0) | 5.7 (0.8) | 44.1 (1.8) | 16.3 (2.8)
| | Uninsured | 211 | 14.3 (4.9)^*^ | 8.2 (2.5)^*^ | 26.0 (6.2) | 51.5 (8.2)
West North Central | MN | Overall | 5,712 | 41.9 (1.3) | 11.0 (0.5) | 32.3 (0.6) | 14.8 (0.9)
| | Private medical with dental | 3,435 | 49.0 (1.3) | 12.8 (0.6) | 25.6 (1.4) | 12.6 (1.2)
| | Private medical without dental | 913 | 30.1 (3.8) | 5.4 (1.4) | 43.6 (4.9) | 20.9 (2.2)
| | Public only | 1,238 | 34.8 (4.7) | 10.1 (1.6) | 42.8 (2.8) | 12.4 (2.4)
| | Uninsured | 126 | --- | --- | --- | ---
| MO | Overall | 6,007 | 36.2 (1.9) | 8.9 (0.8) | 36.6 (1.4) | 18.3 (2.4)
| | Private medical with dental | 3,221 | 49.3 (2.3) | 12.8 (1.5) | 27.4 (1.6) | 10.5 (2.0)
| | Private medical without dental | 1,010 | 20.3 (5.0) | 4.6 (0.9) | 46.6 (3.3) | 28.5 (3.3)
| | Public only | 1,306 | 28.6 (5.8) | 4.0 (1.8)^*^ | 52.7 (5.2) | 14.8 (2.7)
| | Uninsured | 470 | 1.7 (0.7)^*^ | 4.5 (2.3)^*^ | 34.0 (6.4) | 59.8 (7.5)
South Atlantic | FL | Overall | 21,299 | 33.5 (0.9) | 6.3 (0.3) | 37.3 (0.8) | 22.9 (0.8)
| | Private medical with dental | 9,544 | 46.2 (1.2) | 8.2 (0.6) | 28.1 (0.7) | 17.5 (1.2)
| | Private medical without dental | 3,934 | 19.7 (2.2) | 4.1 (0.6) | 49.6 (2.3) | 26.5 (1.5)
| | Public only | 5,553 | 32.8 (1.1) | 3.1 (0.5) | 49.4 (1.0) | 14.7 (0.8)
| | Uninsured | 2,268 | 5.8 (1.0) | 9.5 (1.5) | 25.1 (1.8) | 59.6 (2.9)
| GA | Overall | 10,440 | 32.3 (1.6) | 8.7 (0.5) | 35.5 (1.1) | 23.4 (0.9)
| | Private medical with dental | 5,416 | 40.7 (2.1) | 11.2 (1.2) | 29.4 (1.1) | 18.7 (1.6)
| | Private medical without dental | 1,822 | 25.1 (1.5) | 5.3 (0.8) | 45.5 (2.0) | 24.1 (1.7)
| | Public only | 2,223 | 29.2 (2.9) | 6.2 (1.1) | 45.0 (1.7) | 19.6 (1.9)
| | Uninsured | 979 | 6.4 (0.9) | 7.1 (2.5)^*^ | 29.7 (2.1) | 56.8 (3.4)
| MD | Overall | 6,000 | 39.4 (1.8) | 8.9 (1.2) | 34.8 (1.0) | 17.0 (0.8)
| | Private medical with dental | 4,074 | 48.1 (2.8) | 10.6 (1.4) | 28.4 (0.9) | 12.9 (1.4)
| | Private medical without dental | 641 | 14.7 (1.8) | 3.4 (1.0)^*^ | 49.3 (2.6) | 32.6 (2.5)
| | Public only | 1,050 | 29.0 (2.2) | 5.1 (1.5) | 50.6 (2.6) | 15.3 (2.4)
| | Uninsured | 236 | 2.0 (2.0)^*^ | --- | 34.3 (2.8) | 52.7 (6.5)
| NC | Overall | 10,354 | 33.5 (2.0) | 8.3 (0.8) | 33.6 (0.7) | 24.6 (1.4)
| | Private medical with dental | 5,265 | 46.2 (3.6) | 11.8 (1.4) | 27.0 (1.3) | 15.0 (1.7)
| | Private medical without dental | 1,591 | 23.8 (1.1) | 4.2 (1.4)^*^ | 44.4 (1.3) | 27.7 (2.2)
| | Public only | 2,439 | 24.7 (3.2) | 5.4 (0.5) | 43.9 (2.0) | 26.0 (2.3)
| | Uninsured | 1,059 | 5.4 (1.0) | 4.1 (1.7)^*^ | 26.1 (3.3) | 64.4 (2.7)
| SC | Overall | 5,114 | 38.7 (3.0) | 6.3 (0.9) | 39.2 (3.2) | 15.7 (1.8)
| | Private medical with dental | 3,106 | 49.1 (2.9) | 7.6 (1.7) | 33.0 (3.1) | 10.3 (1.5)
| | Private medical without dental | 664 | 24.4 (3.4) | 2.1 (1.4)^*^ | 53.6 (3.2) | 19.9 (2.9)
| | Public only | 1,124 | 25.1 (4.7) | 4.7 (1.9)^*^ | 50.0 (4.9) | 20.2 (3.4)
| | Uninsured | 221 | 6.0 (3.1)^*^ | 9.1 (4.7)^*^ | 29.0 (5.9) | 55.9 (6.8)
| VA | Overall | 8,367 | 43.2 (2.0) | 8.1 (0.4) | 32.7 (1.7) | 16.1 (0.9)
| | Private medical with dental | 5,132 | 55.6 (2.6) | 9.7 (0.5) | 23.8 (2.2) | 10.9 (0.7)
| | Private medical without dental | 1,418 | 25.3 (2.8) | 7.3 (1.4) | 41.2 (3.4) | 26.2 (3.2)
| | Public only | 1,398 | 25.9 (3.1) | 4.4 (1.3)^*^ | 57.8 (3.0) | 11.9 (1.5)
| | Uninsured | 418 | 8.9 (2.1) | 3.3 (1.4)^*^ | 29.0 (4.4) | 58.8 (4.0)
East South Central | AL | Overall | 4,837 | 36.0 (2.1) | 6.6 (0.6) | 39.2 (0.9) | 18.2 (1.7)
| | Private medical with dental | 2,759 | 46.2 (1.9) | 9.3 (1.1) | 31.5 (1.3) | 13.0 (1.5)
| | Private medical without dental | 680 | 24.2 (4.4) | 0.0 (0.0) | 53.7 (3.9) | 22.1 (5.5)
| | Public only | 1,095 | 25.5 (3.7) | 3.5 (1.0) | 54.7 (3.0) | 16.3 (2.8)
| | Uninsured | 303 | 7.7 (3.5)^*^ | 7.0 (4.9)^*^ | 21.2 (2.0) | 64.1 (5.0)
| KY | Overall | 4,400 | 35.7 (3.4) | 7.0 (0.5) | 39.8 (2.4) | 17.5 (2.6)
| | Private medical with dental | 2,162 | 48.2 (2.9) | 11.0 (0.7) | 27.0 (1.6) | 13.8 (2.3)
| | Private medical without dental | 781 | 22.4 (5.5) | 0.9 (0.6)^*^ | 60.4 (7.4) | 16.3 (2.8)
| | Public only | 1,372 | 25.2 (4.0) | 4.1 (0.6) | 49.8 (2.2) | 20.9 (4.5)
| | Uninsured | 86 | --- | --- | --- | ---
| TN | Overall | 6,677 | 32.5 (1.6) | 9.8 (0.9) | 37.2 (0.8) | 20.6 (1.1)
| | Private medical with dental | 3,654 | 39.8 (1.3) | 12.4 (1.1) | 28.8 (1.3) | 19.1 (1.1)
| | Private medical without dental | 934 | 25.2 (2.6) | 3.7 (0.9) | 51.4 (5.7) | 19.7 (4.7)
| | Public only | 1,780 | 25.0 (2.6) | 8.3 (2.0) | 50.4 (2.4) | 16.4 (2.2)
| | Uninsured | 309 | 11.5 (3.7)^*^ | 6.2 (1.2) | 17.5 (5.5)^*^ | 64.9 (4.6)
West South Central | TX | Overall | 28,545 | 28.8 (0.7) | 9.0 (0.3) | 32.5 (0.8) | 29.7 (0.5)
| | Private medical with dental | 14,556 | 37.1 (1.2) | 12.2 (0.6) | 27.6 (1.0) | 23.1 (1.0)
| | Private medical without dental | 3,949 | 16.8 (1.3) | 5.5 (0.7) | 42.4 (1.2) | 35.3 (1.4)
| | Public only | 6,071 | 32.8 (1.2) | 5.9 (0.7) | 43.3 (1.7) | 17.9 (1.2)
| | Uninsured | 3,969 | 3.9 (0.7) | 5.9 (0.7) | 23.9 (1.4) | 66.3 (2.1)
Mountain | AZ | Overall | 7,210 | 36.5 (1.8) | 9.6 (1.4) | 34.8 (1.6) | 19.1 (1.5)
| | Private medical with dental | 4,008 | 42.6 (3.4) | 11.9 (0.8) | 28.9 (1.1) | 16.6 (3.1)
| | Private medical without dental | 833 | 31.2 (2.4) | 5.4 (3.0)^*^ | 41.7 (3.3) | 21.7 (3.0)
| | Public only | 1,920 | 32.3 (3.2) | 6.7 (3.2)^*^ | 44.2 (3.4) | 16.9 (1.3)
| | Uninsured | 449 | 9.7 (3.0)^*^ | 9.7 (2.2) | 33.8 (4.5) | 46.8 (5.3)
| CO | Overall | 5,639 | 40.9 (1.3) | 11.4 (0.7) | 30.4 (1.9) | 17.3 (0.6)
| | Private medical with dental | 3,005 | 53.0 (1.2) | 14.5 (1.2) | 22.2 (1.7) | 10.3 (1.5)
| | Private medical without dental | 952 | 22.5 (1.8) | 7.9 (1.7) | 48.9 (5.5) | 20.7 (2.8)
| | Public only | 1,358 | 34.8 (4.1) | 5.4 (1.3) | 40.0 (3.1) | 19.8 (2.1)
| | Uninsured | 324 | 8.2 (1.4) | 18.3 (4.4) | 11.9 (3.1) | 61.6 (4.5)
Pacific | CA | Overall | 39,497 | 34.8 (0.8) | 10.0 (0.3) | 31.0 (0.7) | 24.2 (0.6)
| | Private medical with dental | 19,882 | 45.1 (0.9) | 13.6 (0.5) | 23.2 (0.9) | 18.1 (0.7)
| | Private medical without dental | 4,897 | 21.9 (2.1) | 4.8 (0.5) | 45.9 (2.2) | 27.4 (2.2)
| | Public only | 12,603 | 28.6 (1.3) | 7.0 (0.4) | 39.7 (1.2) | 24.8 (1.0)
| | Uninsured | 2,114 | 5.0 (1.2) | 5.5 (0.9) | 18.8 (1.7) | 70.7 (2.3)
| WA | Overall | 7,567 | 43.1 (2.0) | 12.9 (1.3) | 26.5 (0.7) | 17.5 (1.2)
| | Private medical with dental | 4,315 | 49.8 (2.8) | 16.6 (1.5) | 20.4 (0.9) | 13.2 (1.4)
| | Private medical without dental | 956 | 26.1 (2.3) | 6.4 (1.4) | 40.3 (2.5) | 27.2 (4.4)
| | Public only | 2,000 | 41.4 (2.6) | 9.0 (1.4) | 33.9 (1.5) | 15.7 (1.9)
| | Uninsured | 295 | 11.3 (2.8) | 7.1 (2.3)^*^ | 21.0 (4.3) | 60.6 (4.4)

* Standard errors for estimates appear in parentheses.

--- Estimate suppressed due to small sample size.

* Estimate has high relative standard error.

Dental includes any visit to any type of dental provider.

Medical includes any visit to any office-based, outpatient, inpatient, emergency room, or home health provider.

Source: Agency for Healthcare Research and Quality, Center for Financing, Access and Cost Trends, MEPS-HC, 2018–2019.