# STATISTICAL BRIEF #537 Trends in the Number and Percentage of the Population with Any Dental or Medical Visits, 2003–2018

## Highlights

■ About 37 percent of Americans (121.2 million in 2018) visited a dentist and a physician at least once a year, and another 9 percent (28.2 million in 2018) visited only a dentist.
■ The percentage visiting both a physician and a dentist in 2018 was higher among persons who are non-Hispanic White (43.7 percent) compared to those who are Hispanic (26.2 percent) or non-Hispanic Black (25.8 percent).
■ Persons who are non-Hispanic White, non-Hispanic other, male, aged 6 to 64, and living in the West and Midwest are more likely to visit a dentist only.

## Introduction

In 2000, the first-ever Surgeon General’s Report on oral health was released. Oral Health in America provided numerous examples of the connection between oral health and overall health, concluding that “oral health means much more than healthy teeth” and “is essential to the general health and well-being of all Americans.”^1^ Since the publication of that report, there has been a concerted effort to better integrate oral health and overall health across the country. Full integration is multidirectional, incorporating oral health into different aspects of overall health (medical care, behavioral health, pharmacy care, etc.) and incorporating overall health concepts into dental practices. For example, the American Dental Association, the nation’s largest dentist organization, has estimated that healthcare costs in the United States could be reduced by over $100 million each year through screening for chronic diseases in dental offices.^2^

To provide a foundation for multidirectional integration of oral health and overall health, we examined the number and percentage of persons with any dental and medical visits using 2003 to 2018 data from the Medical Expenditure Panel Survey-Household Component. A dental visit included any reported visit in the year to any type of dental provider, including general dentists, specialists, hygienists, and technicians. A medical visit included any reported visit in the year to any type of physician or nonphysician provider in an office-based, inpatient, outpatient, emergency room, or home health setting.

## Findings

All differences between estimates discussed in the text are statistically significant at the 0.05 level or better unless otherwise noted.

### U.S. medical and dental visits (tables 1–2, figure 1)

As shown in table 1 and figure 1, 121.2 million Americans had both a medical and dental visit in 2018, an 18 percent increase from 2003. Though this increase was driven mostly by population growth, more Americans than ever before reported visiting only a dental provider in the past year (28.2 million, up 11 percent from 2003) or having neither visited a medical nor a dental provider in the past year (64.7 million, up 18 percent from 2003).

As seen in table 2 and figure 1, the percentage of Americans exclusively visiting medical providers and not dental providers decreased in 2018 to its lowest point in two decades, with only 34.4 percent (down from 37.0 percent in 2003) visiting just a medical provider in 2018. The percentage of people with just a dental visit did not change significantly from 2003 to 2018, however, at around 8.6 percent. But the overall percentage of Americans with a dental visit, including those with a medical visit, rose from 44.0 percent in 2003 to 45.7 percent in 2018.

### Medical and dental visits by race/ethnicity (table 2, figure 2)

As seen in table 2 and figure 2, significant disparities exist between racial/ethnic groups in healthcare utilization. Among persons who are non-Hispanic White, 43.7 percent visited both a medical and dental provider in 2018, compared to just 26.2 percent of those who are Hispanic and 25.8 percent of those who are non-Hispanic Black. Similarly, more Hispanics (31.0 percent) had neither a dental nor medical visit in 2018, compared to non-Hispanic Blacks (25.3 percent) and non-Hispanic Whites (14.6 percent). More non-Hispanic Blacks (40.7 percent) had only a medical visit in 2018, compared to Hispanics (34.5 percent) and non-Hispanic Whites (33.1 percent).

### Medical and dental visits by age (tables 1–2, figure 2)

Healthcare visits by children and adolescents ages 0 to 5 and ages 6 to 17 years increased from 2003 to 2018. The percentage with visits to both a medical and dental provider increased from 20.1 percent to 29.0 percent and from 42.2 percent to 46.3 percent for the two age groups, respectively. The percentage with only medical visits dropped from 66.1 percent in 2003 to 54.6 percent in 2018 for children ages 0 to 5.

Among adults 65 years and older, 27.9 million had a dental visit in 2018, up from 15.4 million in 2003. The overall percentage of Americans 65 years of age and older with a dental visit increased from 42.0 percent in 2003 to 51.0 percent in 2018, while the percentage of those having a dental visit only but not a medical visit remained steady at 1.6 percent.

### Medical and dental visits by region (table 2, figure 2)

Disparities in dental utilization were also based on geographic location. Only 41.5 percent of Americans in the South had a dental visit in 2018, compared to 47.5 percent in the Northeast, 49.9 percent in the Midwest, and 47.8 percent in the West. However, people living in the West (10.2 percent) were most likely to have had a dental visit but not a medical visit compared to those in the Northeast (7.6 percent). People living in the South (21.9 percent) and West (21.7 percent) were most likely to have neither a medical nor a dental visit in 2018 compared to those in the Northeast (17.2 percent) and Midwest (16.0 percent).

## Data Source

This Statistical Brief uses data from the following public use data files:

Data Files | 2003 | 2006 | 2009 | 2012 | 2015 | 2018
Full-Year Consolidated | HC-79 | HC-105 | HC-129 | HC-155 | HC-181 | HC-209
Dental events | HC-77B | HC-102B | HC-126B | HC-152B | HC-178B | HC-206B
Inpatient events | HC-77D | HC-102D | HC-126D | HC-152D | HC-178D | HC-206D
Emergency room events | HC-77E | HC-102E | HC-126E | HC-152E | HC-178E | HC-206E
Outpatient events | HC-77F | HC-102F | HC-126F | HC-152F | HC-178F | HC-206F
Office-based events | HC-77G | HC-102G | HC-126G | HC-152G | HC-178G | HC-206G
Home health events | HC-77H | HC-102H | HC-126H | HC-152H | HC-178H | HC-206H

## Definitions

### Dental visits

A dental visit is an in-person visit to any type of dental provider, including general dentists and specialists such as periodontists, as well as non-dentists such as hygienists and technicians.

### Medical visits

A medical visit is an in-person visit to any type of medical provider, including physicians (medical doctors) and non-physicians (e.g., nurses, technicians) in an office-based, inpatient, outpatient, emergency room, or home health setting.

### Race/ethnicity

Classification by race/ethnicity was based on information reported for each family member. First, respondents were asked if the person’s main national origin or ancestry was Puerto Rican; Cuban; Mexican, Mexican American, or Chicano; other Latin American; or other Spanish. All persons whose main national origin or ancestry was reported in one of these Hispanic groups, regardless of racial background, were classified as Hispanic. All other persons were classified according to their reported race. For this analysis, the following classification by race and ethnicity was used: Hispanic, non-Hispanic Black, non-Hispanic White, and non-Hispanic other. The other category includes American Indian, Alaska Native, Asian or Pacific Islander, other race, and multiple races.

### Age

The age variable is based on the sample person’s age as of the end of the year. If data were not collected during a round because the sample person was out of scope (e.g., deceased or institutionalized), then age at the time of the previous round was used.

### Census region

The Census region variable is based on the location of the household at the end of the year. If missing, the most recent location available is used.

Region | Included States
Northeast | Connecticut, Maine, Massachusetts, New Hampshire, New Jersey, New York, Pennsylvania, Rhode Island, and Vermont
Midwest | Illinois, Indiana, Iowa, Kansas, Michigan, Minnesota, Missouri, Nebraska, North Dakota, Ohio, South Dakota, and Wisconsin
South | Alabama, Arkansas, Delaware, District of Columbia, Florida, Georgia, Kentucky, Louisiana, Maryland, Mississippi, North Carolina, Oklahoma, South Carolina, Tennessee, Texas, Virginia, West Virginia
West | Alaska, Arizona, California, Colorado, Hawaii, Idaho, Montana, Nevada, New Mexico, Oregon, Utah, Washington, and Wyoming

## About MEPS

The Medical Expenditure Panel Survey Household Component (MEPS-HC) collects nationally representative data on healthcare use, expenditures, sources of payment, and insurance coverage for the U.S. civilian noninstitutionalized population. The MEPS-HC is cosponsored by the Agency for Healthcare Research and Quality (AHRQ) and the National Center for Health Statistics (NCHS). More information about the MEPS-HC can be found on the Medical Expenditure Panel Survey (MEPS) website at http://www.meps.ahrq.gov.

## References

American Dental Association, Health Policy Institute. Screening for Chronic Diseases in the Dental Office. 2018. Accessed August 16, 2021, at https://www.ada.org/~/media/ADA/Science percent20and percent20Research/HPI/Files/ADA_HPI_DentalOfcScreening.pdf?la=en (https://nam11.safelinks.protection.outlook.com/?url=https%3A%2F%2Fwww.ada.org%2F%7E%2Fmedia%2FADA%2FScience%2520and%2520Research%2FHPI%2FFiles%2FADA_HPI_DentalOfcScreening.pdf%3Fla%3Den&data=04%7C01%7CRManski%40umaryland.edu%7C514307b37abf4dde9b3b08d96104fc01%7C3dcdbc4a7e4c407b80f77fb6757182f2%7C0%7C0%7C637647496753078466%7CUnknown%7CTWFpbGZsb3d8eyJWIjoiMC4wLjAwMDAiLCJQIjoiV2luMzIiLCJBTiI6Ik1haWwiLCJXVCI6Mn0%3D%7C1000&sdata=o8B0Sb7GSjM%2B5ie9jWtnY63ffEVOIWyDM%2FaVrOimuag%3D&reserved=0)
U.S. Department of Health and Human Services. Oral Health in America: A Report of the Surgeon General. 2000. U.S. Department of Health and Human Services, National Institute of Dental and Craniofacial Research, National Institutes of Health, Rockville, MD.

## Suggested Citation

Manski, R., Rohde, F., and Ricks, T. Trends in the Number and Percentage of the Population with Any Dental or Medical Visits, 2003–2018. Statistical Brief #537. October 2021. Agency for Healthcare Research and Quality, Rockville, MD. https://meps.ahrq.gov/data_files/publications/st537/stat537.pdf

AHRQ welcomes questions and comments from readers of this publication who are interested in obtaining more information about access, cost, use, financing, and quality of healthcare in the United States. We also invite you to tell us how you are using this Statistical Brief and other MEPS data and tools and to share suggestions on how MEPS products might be enhanced to further meet your needs. Please email us at MEPSProjectDirector@ahrq.hhs.gov or send a letter to the address below:

Joel W. Cohen, PhD, Director
Center for Financing, Access and Cost Trends
Agency for Healthcare Research and Quality
5600 Fishers Lane, Mailstop 07W41A
Rockville, MD 20857

1 U.S. Department of Health and Human Services. Oral Health in America: A Report of the Surgeon General. 2000. U.S. Department of Health and Human Services, National Institute of Dental and Craniofacial Research, National Institutes of Health, Rockville, MD.

2 American Dental Association, Health Policy Institute. Screening for Chronic Diseases in the Dental Office. 2018. Accessed August 16, 2021, at https://www.ada.org/~/media/ADA/Science percent20and percent20Research/HPI/Files/ADA_HPI_DentalOfcScreening.pdf?la=en (https://nam11.safelinks.protection.outlook.com/?url=https%3A%2F%2Fwww.ada.org%2F%7E%2Fmedia%2FADA%2FScience%2520and%2520Research%2FHPI%2FFiles%2FADA_HPI_DentalOfcScreening.pdf%3Fla%3Den&data=04%7C01%7CRManski%40umaryland.edu%7C514307b37abf4dde9b3b08d96104fc01%7C3dcdbc4a7e4c407b80f77fb6757182f2%7C0%7C0%7C637647496753078466%7CUnknown%7CTWFpbGZsb3d8eyJWIjoiMC4wLjAwMDAiLCJQIjoiV2luMzIiLCJBTiI6Ik1haWwiLCJXVCI6Mn0%3D%7C1000&sdata=o8B0Sb7GSjM%2B5ie9jWtnY63ffEVOIWyDM%2FaVrOimuag%3D&reserved=0)

Table 1 Population with any dental or medical visits

Demographic | Total population (millions)^*^
Visit category^^^ | 2003 | 2006 | 2009 | 2012 | 2015 | 2018
All persons
Dental and medical | 102.6 (2.6) | 102.8 (3.0) | 104.5 (2.9) | 104.7 (3.1) | 109.6 (3.4) | 121.2 (3.5)
Dental only | 25.4 (0.9) | 26.2 (0.9) | 24.9 (0.9) | 25.2 (0.9) | 28.2 (1.1) | 28.2 (1.0)
Medical only | 107.6 (2.5) | 110.0 (2.8) | 114.4 (2.7) | 119.5 (2.6) | 119.3 (3.1) | 112.3 (2.7)
Neither dental nor medical | 55.0 (1.7) | 60.2 (2.0) | 62.9 (1.9) | 64.1 (1.9) | 64.3 (2.0) | 64.7 (1.9)
Race/ethnicity
Hispanic, any race
Dental and medical | 8.1 (0.5) | 8.7 (0.5) | 10.2 (0.7) | 11.8 (0.8) | 14.0 (0.9) | 15.8 (0.9)
Dental only | 3.0 (0.2) | 3.3 (0.2) | 3.5 (0.2) | 4.2 (0.3) | 4.9 (0.3) | 5.0 (0.4)
Medical only | 16.2 (0.9) | 18.0 (1.0) | 19.2 (1.3) | 21.1 (1.5) | 21.3 (1.3) | 20.8 (1.2)
Neither dental nor medical | 13.4 (0.8) | 15.2 (1.0) | 16.2 (1.2) | 16.3 (1.1) | 16.8 (1.3) | 18.7 (1.1)
Non-Hispanic White
Dental and medical | 81.3 (2.4) | 79.9 (2.6) | 79.6 (2.7) | 77.4 (2.9) | 77.2 (2.9) | 85.1 (3.0)
Dental only | 18.1 (0.8) | 18.0 (0.7) | 16.3 (0.7) | 15.9 (0.8) | 17.2 (1.0) | 16.7 (0.8)
Medical only | 69.1 (1.9) | 69.1 (2.0) | 71.6 (2.2) | 73.2 (2.2) | 69.4 (2.3) | 64.5 (2.1)
Neither dental nor medical | 27.7 (1.0) | 30.0 (1.1) | 31.4 (1.2) | 31.4 (1.3) | 30.2 (1.4) | 28.4 (1.3)
Non-Hispanic Black
Dental and medical | 7.7 (0.5) | 8.2 (0.5) | 8.5 (0.5) | 8.7 (0.5) | 9.0 (0.5) | 10.3 (0.7)
Dental only | 2.4 (0.2) | 2.9 (0.3) | 2.6 (0.3) | 2.7 (0.2) | 2.9 (0.2) | 3.3 (0.3)
Medical only | 15.9 (0.8) | 15.7 (0.9) | 15.8 (0.9) | 16.5 (1.0) | 17.2 (1.0) | 16.3 (0.9)
Neither dental nor medical | 9.2 (0.6) | 9.4 (0.6) | 9.9 (0.7) | 10.0 (0.6) | 10.4 (0.6) | 10.1 (0.6)
Non-Hispanic other
Dental and medical | 5.4 (0.4) | 6.0 (0.5) | 6.1 (0.6) | 6.8 (0.5) | 9.3 (0.8) | 10.0 (0.7)
Dental only | 1.9 (0.2) | 2.0 (0.3) | 2.5 (0.2) | 2.3 (0.2) | 3.2 (0.3) | 3.2 (0.3)
Medical only | 6.4 (0.5) | 7.2 (0.6) | 7.7 (0.6) | 8.7 (0.7) | 11.4 (1.0) | 10.6 (0.6)
Neither dental nor medical | 4.7 (0.4) | 5.5 (0.6) | 5.4 (0.4) | 6.3 (0.6) | 6.8 (0.6) | 7.5 (0.5)
Sex
Male
Dental and medical | 43.0 (1.2) | 43.9 (1.4) | 44.4 (1.3) | 44.9 (1.6) | 47.6 (1.7) | 53.2 (1.6)
Dental only | 14.4 (0.6) | 14.8 (0.6) | 13.9 (0.5) | 13.9 (0.6) | 15.3 (0.7) | 15.4 (0.7)
Medical only | 50.0 (1.3) | 51.3 (1.4) | 53.5 (1.4) | 55.3 (1.3) | 55.4 (1.5) | 52.7 (1.4)
Neither dental nor medical | 34.9 (1.1) | 37.0 (1.3) | 38.7 (1.2) | 39.1 (1.2) | 38.9 (1.2) | 38.4 (1.2)
Female
Dental and medical | 59.6 (1.5) | 58.9 (1.8) | 60.0 (1.8) | 59.8 (1.7) | 62.0 (1.9) | 68.0 (2.1)
Dental only | 11.0 (0.5) | 11.5 (0.5) | 11.0 (0.5) | 11.3 (0.5) | 13.0 (0.6) | 12.8 (0.5)
Medical only | 57.6 (1.4) | 58.7 (1.6) | 60.8 (1.5) | 64.2 (1.6) | 63.9 (1.8) | 59.6 (1.5)
Neither dental nor medical | 20.1 (0.8) | 23.2 (0.9) | 24.2 (0.8) | 25.0 (0.8) | 25.4 (1.0) | 26.2 (0.9)
Age group
0-5
Dental and medical | 4.6 (0.3) | 5.3 (0.4) | 5.9 (0.4) | 5.2 (0.3) | 6.3 (0.4) | 6.8 (0.4)
Dental only | 0.8 (0.1) | 0.8 (0.1) | 0.7 (0.1) | 1.0 (0.1) | 0.7 (0.1) | 1.1 (0.2)
Medical only | 15.3 (0.6) | 15.1 (0.6) | 15.7 (0.6) | 14.9 (0.6) | 14.4 (0.7) | 12.9 (0.6)
Neither dental nor medical | 2.4 (0.2) | 3.1 (0.2) | 3.5 (0.2) | 3.0 (0.2) | 2.6 (0.2) | 2.7 (0.2)
6-17
Dental and medical | 21.0 (0.8) | 20.2 (0.8) | 20.7 (0.9) | 21.5 (1.0) | 21.2 (1.0) | 23.2 (1.0)
Dental only | 7.2 (0.4) | 8.2 (0.4) | 6.5 (0.4) | 7.4 (0.4) | 8.4 (0.5) | 7.0 (0.4)
Medical only | 12.4 (0.5) | 11.4 (0.5) | 12.4 (0.5) | 12.0 (0.6) | 11.8 (0.6) | 11.5 (0.7)
Neither dental nor medical | 9.2 (0.5) | 9.8 (0.5) | 9.3 (0.4) | 9.0 (0.5) | 8.7 (0.5) | 8.4 (0.4)
18-64
Dental and medical | 62.1 (1.7) | 61.3 (1.9) | 60.7 (1.9) | 58.8 (1.9) | 60.0 (2.1) | 64.2 (2.1)
Dental only | 16.8 (0.6) | 16.5 (0.6) | 16.9 (0.6) | 16.0 (0.6) | 18.1 (0.8) | 19.2 (0.8)
Medical only | 60.9 (1.6) | 64.3 (1.7) | 66.5 (1.8) | 70.3 (1.7) | 69.7 (1.9) | 64.6 (1.7)
Neither dental nor medical | 41.1 (1.2) | 45.0 (1.5) | 47.3 (1.5) | 49.2 (1.5) | 49.9 (1.6) | 50.1 (1.5)
65+
Dental and medical | 14.8 (0.8) | 15.9 (0.7) | 17.1 (0.8) | 19.2 (1.0) | 22.1 (1.0) | 27.0 (0.9)
Dental only | 0.6 (0.1) | 0.7 (0.1) | 0.8 (0.1) | 0.8 (0.1) | 1.1 (0.1) | 0.9 (0.1)
Medical only | 18.9 (0.7) | 19.2 (0.7) | 19.7 (0.7) | 22.3 (0.8) | 23.3 (0.9) | 23.3 (0.8)
Neither dental nor medical | 2.4 (0.2) | 2.3 (0.2) | 2.8 (0.2) | 3.0 (0.2) | 3.1 (0.3) | 3.5 (0.2)
Region
Northeast
Dental and medical | 22.1 (1.1) | 21.8 (1.3) | 21.3 (1.6) | 20.4 (1.4) | 21.5 (1.6) | 22.2 (1.6)
Dental only | 4.0 (0.4) | 4.5 (0.3) | 3.5 (0.3) | 3.5 (0.3) | 4.2 (0.4) | 4.2 (0.4)
Medical only | 19.5 (1.0) | 19.9 (1.1) | 20.6 (1.1) | 21.5 (1.1) | 20.7 (1.0) | 19.6 (1.1)
Neither dental nor medical | 8.4 (0.5) | 8.5 (0.6) | 9.8 (0.7) | 10.3 (0.6) | 10.1 (0.7) | 9.6 (0.8)
Midwest
Dental and medical | 25.6 (1.5) | 25.3 (1.5) | 25.3 (1.3) | 25.7 (1.6) | 26.0 (1.8) | 27.8 (1.2)
Dental only | 6.2 (0.4) | 6.2 (0.5) | 6.1 (0.4) | 6.0 (0.4) | 6.3 (0.5) | 6.2 (0.4)
Medical only | 23.0 (1.2) | 23.4 (1.3) | 23.6 (0.9) | 24.3 (0.9) | 23.7 (1.2) | 23.3 (1.2)
Neither dental nor medical | 10.6 (0.7) | 11.0 (0.8) | 12.0 (0.8) | 10.9 (0.7) | 11.8 (0.6) | 10.9 (0.7)
South
Dental and medical | 32.3 (1.3) | 33.2 (1.7) | 34.6 (1.4) | 34.6 (1.8) | 36.2 (1.7) | 41.9 (1.9)
Dental only | 8.1 (0.5) | 8.2 (0.5) | 8.0 (0.5) | 8.2 (0.5) | 9.3 (0.6) | 9.9 (0.5)
Medical only | 42.2 (1.5) | 43.4 (1.8) | 45.6 (1.6) | 48.6 (1.6) | 49.1 (2.2) | 45.5 (1.7)
Neither dental nor medical | 21.7 (1.1) | 24.2 (1.4) | 24.7 (1.1) | 25.6 (1.1) | 26.4 (1.4) | 27.3 (1.1)
West
Dental and medical | 22.5 (1.2) | 22.4 (1.4) | 23.3 (1.2) | 24.0 (1.1) | 25.9 (1.3) | 29.3 (2.1)
Dental only | 7.1 (0.5) | 7.3 (0.5) | 7.4 (0.5) | 7.5 (0.4) | 8.4 (0.7) | 7.9 (0.7)
Medical only | 22.8 (1.3) | 23.3 (1.3) | 24.6 (1.3) | 25.1 (1.0) | 25.8 (1.2) | 23.8 (1.3)
Neither dental nor medical | 14.3 (1.0) | 16.5 (1.0) | 16.4 (0.8) | 17.3 (1.0) | 16.0 (1.0) | 16.9 (1.0)

* Standard errors for estimates appear in parentheses.

^ Dental includes any visit to any type of dental provider. Medical includes any visit to any office-based, outpatient, inpatient, emergency room or home health provider.

Source: Agency for Healthcare Research and Quality, Center for Financing, Access and Cost Trends, Medical Expenditure Panel Survey, Household Component, 2003-2018.

Table 2 Percentage of population with any dental or medical visits

Demographic | Percentage of population^*^
Visit category^^^ | 2003 | 2006 | 2009 | 2012 | 2015 | 2018
All persons
Dental and medical | 35.3 (0.5) | 34.3 (0.5) | 34.1 (0.6) | 33.4 (0.6) | 34.1 (0.6) | 37.1 (0.6)
Dental only | 8.7 (0.2) | 8.8 (0.2) | 8.1 (0.2) | 8.0 (0.2) | 8.8 (0.3) | 8.6 (0.2)
Medical only | 37.0 (0.4) | 36.8 (0.4) | 37.3 (0.4) | 38.1 (0.5) | 37.1 (0.5) | 34.4 (0.4)
Neither dental nor medical | 18.9 (0.4) | 20.1 (0.4) | 20.5 (0.4) | 20.4 (0.4) | 20.0 (0.4) | 19.8 (0.4)
Race/ethnicity
Hispanic, any race
Dental and medical | 20.0 (0.8) | 19.2 (0.7) | 20.7 (0.7) | 22.1 (0.7) | 24.6 (0.8) | 26.2 (0.9)
Dental only | 7.3 (0.4) | 7.3 (0.4) | 7.1 (0.4) | 7.9 (0.4) | 8.6 (0.4) | 8.3 (0.5)
Medical only | 39.8 (0.9) | 39.8 (0.8) | 39.1 (0.8) | 39.4 (0.7) | 37.4 (0.7) | 34.5 (0.9)
Neither dental nor medical | 33.0 (0.9) | 33.8 (0.9) | 33.0 (0.9) | 30.5 (0.8) | 29.5 (0.9) | 31.0 (0.8)
Non-Hispanic White
Dental and medical | 41.4 (0.7) | 40.5 (0.6) | 40.0 (0.7) | 39.1 (0.7) | 39.8 (0.8) | 43.7 (0.8)
Dental only | 9.2 (0.3) | 9.1 (0.3) | 8.2 (0.3) | 8.0 (0.3) | 8.9 (0.4) | 8.6 (0.3)
Medical only | 35.2 (0.6) | 35.1 (0.5) | 36.0 (0.6) | 37.0 (0.6) | 35.8 (0.7) | 33.1 (0.6)
Neither dental nor medical | 14.1 (0.4) | 15.2 (0.3) | 15.8 (0.5) | 15.9 (0.5) | 15.6 (0.5) | 14.6 (0.5)
Non-Hispanic Black
Dental and medical | 21.9 (0.9) | 22.7 (0.8) | 23.0 (0.9) | 23.0 (0.9) | 22.8 (0.8) | 25.8 (1.0)
Dental only | 6.9 (0.5) | 8.0 (0.6) | 7.1 (0.5) | 7.2 (0.4) | 7.4 (0.4) | 8.3 (0.7)
Medical only | 45.0 (0.8) | 43.3 (0.9) | 42.9 (0.8) | 43.5 (1.0) | 43.4 (0.8) | 40.7 (1.2)
Neither dental nor medical | 26.2 (1.0) | 26.0 (0.8) | 26.9 (0.8) | 26.3 (0.8) | 26.4 (0.9) | 25.3 (1.1)
Non-Hispanic other
Dental and medical | 29.4 (1.5) | 28.9 (1.4) | 28.4 (1.3) | 28.2 (1.4) | 30.2 (1.2) | 31.9 (1.5)
Dental only | 10.4 (0.9) | 9.6 (1.0) | 11.5 (0.8) | 9.7 (0.8) | 10.5 (0.7) | 10.2 (0.7)
Medical only | 34.7 (1.4) | 34.9 (1.6) | 35.4 (1.3) | 35.8 (1.2) | 37.1 (1.1) | 33.9 (1.5)
Neither dental nor medical | 25.4 (1.3) | 26.6 (1.8) | 24.7 (1.2) | 26.3 (1.3) | 22.2 (1.1) | 23.9 (1.1)
Sex
Male
Dental and medical | 30.2 (0.6) | 29.9 (0.5) | 29.5 (0.6) | 29.3 (0.7) | 30.3 (0.7) | 33.3 (0.6)
Dental only | 10.1 (0.3) | 10.0 (0.3) | 9.3 (0.3) | 9.1 (0.3) | 9.7 (0.3) | 9.6 (0.4)
Medical only | 35.1 (0.5) | 34.9 (0.5) | 35.6 (0.5) | 36.1 (0.6) | 35.3 (0.6) | 33.0 (0.5)
Neither dental nor medical | 24.5 (0.5) | 25.2 (0.5) | 25.7 (0.5) | 25.5 (0.5) | 24.8 (0.5) | 24.1 (0.5)
Female
Dental and medical | 40.2 (0.6) | 38.7 (0.6) | 38.5 (0.7) | 37.3 (0.6) | 37.8 (0.7) | 40.8 (0.7)
Dental only | 7.4 (0.3) | 7.5 (0.3) | 7.1 (0.3) | 7.0 (0.3) | 7.9 (0.3) | 7.7 (0.3)
Medical only | 38.8 (0.5) | 38.5 (0.5) | 39.0 (0.6) | 40.1 (0.6) | 38.9 (0.6) | 35.7 (0.6)
Neither dental nor medical | 13.6 (0.4) | 15.2 (0.4) | 15.5 (0.4) | 15.6 (0.4) | 15.5 (0.5) | 15.8 (0.4)
Age group
0-5
Dental and medical | 20.1 (1.0) | 21.9 (1.1) | 23.0 (1.1) | 21.5 (1.1) | 26.1 (1.4) | 29.0 (1.3)
Dental only | 3.5 (0.4) | 3.5 (0.5) | 2.9 (0.4) | 4.1 (0.5) | 3.0 (0.4) | 4.8 (0.7)
Medical only | 66.1 (1.1) | 61.8 (1.3) | 60.7 (1.2) | 62.1 (1.2) | 60.1 (1.5) | 54.6 (1.2)
Neither dental nor medical | 10.3 (0.7) | 12.8 (0.8) | 13.4 (0.8) | 12.3 (0.9) | 10.8 (0.9) | 11.5 (0.9)
6-17
Dental and medical | 42.2 (0.9) | 40.7 (1.1) | 42.3 (1.1) | 43.2 (1.1) | 42.3 (1.1) | 46.3 (1.3)
Dental only | 14.4 (0.6) | 16.5 (0.6) | 13.3 (0.7) | 14.8 (0.6) | 16.8 (0.8) | 14.0 (0.8)
Medical only | 24.9 (0.8) | 23.0 (0.7) | 25.3 (0.9) | 24.0 (0.9) | 23.6 (1.0) | 22.9 (1.0)
Neither dental nor medical | 18.5 (0.7) | 19.7 (0.7) | 19.1 (0.7) | 18.0 (0.9) | 17.3 (0.8) | 16.8 (0.7)
18-64
Dental and medical | 34.3 (0.6) | 32.8 (0.6) | 31.7 (0.7) | 30.3 (0.6) | 30.4 (0.7) | 32.4 (0.6)
Dental only | 9.3 (0.3) | 8.8 (0.3) | 8.8 (0.3) | 8.2 (0.3) | 9.1 (0.3) | 9.7 (0.3)
Medical only | 33.7 (0.5) | 34.4 (0.5) | 34.7 (0.5) | 36.2 (0.5) | 35.2 (0.5) | 32.6 (0.5)
Neither dental nor medical | 22.7 (0.4) | 24.1 (0.5) | 24.7 (0.5) | 25.3 (0.5) | 25.3 (0.6) | 25.3 (0.5)
65+
Dental and medical | 40.3 (1.3) | 41.8 (1.1) | 42.3 (1.1) | 42.3 (1.3) | 44.6 (1.2) | 49.4 (1.0)
Dental only | 1.7 (0.2) | 1.8 (0.3) | 1.9 (0.3) | 1.8 (0.3) | 2.2 (0.3) | 1.6 (0.2)
Medical only | 51.5 (1.1) | 50.5 (1.1) | 49.0 (1.0) | 49.2 (1.2) | 47.1 (1.2) | 42.7 (0.9)
Neither dental nor medical | 6.5 (0.5) | 6.0 (0.4) | 6.9 (0.5) | 6.7 (0.5) | 6.2 (0.5) | 6.4 (0.4)
Region
Northeast
Dental and medical | 41.0 (1.4) | 39.9 (1.2) | 38.6 (1.7) | 36.7 (1.5) | 38.1 (1.4) | 39.9 (1.3)
Dental only | 7.5 (0.6) | 8.2 (0.5) | 6.3 (0.5) | 6.2 (0.4) | 7.4 (0.7) | 7.6 (0.5)
Medical only | 36.1 (1.2) | 36.4 (1.2) | 37.3 (1.2) | 38.6 (1.1) | 36.6 (1.1) | 35.3 (1.0)
Neither dental nor medical | 15.5 (0.7) | 15.4 (0.8) | 17.8 (1.0) | 18.5 (0.9) | 17.9 (1.0) | 17.2 (0.8)
Midwest
Dental and medical | 39.1 (1.1) | 38.4 (0.9) | 37.8 (1.3) | 38.4 (1.3) | 38.3 (1.5) | 40.8 (1.1)
Dental only | 9.4 (0.4) | 9.4 (0.4) | 9.0 (0.5) | 9.0 (0.5) | 9.3 (0.6) | 9.1 (0.5)
Medical only | 35.2 (0.9) | 35.5 (0.9) | 35.3 (0.9) | 36.4 (1.0) | 35.0 (1.2) | 34.2 (1.0)
Neither dental nor medical | 16.2 (0.8) | 16.7 (0.6) | 17.9 (0.9) | 16.3 (0.8) | 17.5 (0.7) | 16.0 (0.7)
South
Dental and medical | 31.0 (0.8) | 30.4 (0.9) | 30.7 (0.8) | 29.6 (0.9) | 29.9 (0.8) | 33.6 (1.0)
Dental only | 7.8 (0.4) | 7.6 (0.3) | 7.1 (0.4) | 7.0 (0.4) | 7.7 (0.4) | 7.9 (0.4)
Medical only | 40.4 (0.7) | 39.8 (0.8) | 40.4 (0.7) | 41.6 (0.8) | 40.6 (0.6) | 36.5 (0.7)
Neither dental nor medical | 20.8 (0.7) | 22.2 (0.7) | 21.9 (0.6) | 21.8 (0.7) | 21.8 (0.8) | 21.9 (0.7)
West
Dental and medical | 33.7 (0.9) | 32.3 (1.0) | 32.5 (1.0) | 32.5 (0.9) | 34.0 (1.2) | 37.6 (1.3)
Dental only | 10.6 (0.6) | 10.5 (0.5) | 10.4 (0.5) | 10.1 (0.4) | 11.1 (0.6) | 10.2 (0.5)
Medical only | 34.2 (0.8) | 33.5 (0.7) | 34.3 (0.9) | 33.9 (0.7) | 33.9 (1.1) | 30.5 (0.8)
Neither dental nor medical | 21.4 (0.7) | 23.8 (0.9) | 22.9 (0.6) | 23.5 (0.9) | 21.0 (0.7) | 21.7 (1.0)

* Standard errors for estimates appear in parentheses.

^ Dental includes any visit to any type of dental provider. Medical includes any visit to any office-based, outpatient, inpatient, emergency room or home health provider.

Source: Agency for Healthcare Research and Quality, Center for Financing, Access and Cost Trends, Medical Expenditure Panel Survey, Household Component, 2003-2018.

Figure 1 Population with any dental and medical visits

Dental includes any visit to any type of dental provider. Medical includes any visit to any office-based, outpatient, inpatient, emergency room, or home health provider.

Two Bar Graphs depicting population with any dental and medical visits

Provider Visit Category | 2003 | 2006 | 2009 | 2012 | 2015 | 2018
In Millions
Dental and medical | 102.6 | 102.8 | 104.5 | 104.7 | 109.6 | 121.2
Dental only | 25.4 | 26.2 | 24.9 | 25.2 | 28.2 | 28.2
Medical only | 107.6 | 110.0 | 114.4 | 119.5 | 119.3 | 112.3
Neither dental nor medical | 55.0 | 60.2 | 62.9 | 64.1 | 64.3 | 64.7
Percentages
Dental and medical | 35.3 | 34.3 | 34.1 | 33.4 | 34.1 | 37.1
Dental only | 8.7 | 8.8 | 8.1 | 8.0 | 8.8 | 8.6
Medical only | 37.0 | 36.8 | 37.3 | 38.1 | 37.1 | 34.4
Neither dental nor medical | 18.9 | 20.1 | 20.5 | 20.4 | 20.0 | 19.8

Source: Agency for Healthcare Research and Quality, Center for Financing, Access and Cost Trends, Medical Expenditure Panel Survey, Household Component, 2003-2018.

Figure 2 Percentage with only dental visits by demographic

Four Line Graphs depicting percentage with only dental visits by demographic

Demographic | 2003 | 2006 | 2009 | 2012 | 2015 | 2018
Race/ethnicity
Hispanic, any race | 7.3 | 7.3 | 7.1 | 7.9 | 8.6 | 8.3
Non-Hispanic White | 9.2 | 9.1 | 8.2 | 8.0 | 8.9 | 8.6
Non-Hispanic Black | 6.9 | 8.0 | 7.1 | 7.2 | 7.4 | 8.3
Non-Hispanic other | 10.4 | 9.6 | 11.5 | 9.7 | 10.5 | 10.2
Sex
Male | 10.1 | 10.0 | 9.3 | 9.1 | 9.7 | 9.6
Female | 7.4 | 7.5 | 7.1 | 7.0 | 7.9 | 7.7
Age group
0-5 | 3.5 | 3.5 | 2.9 | 4.1 | 3.0 | 4.8
6-17 | 14.4 | 16.5 | 13.3 | 14.8 | 16.8 | 14.0
18-64 | 9.3 | 8.8 | 8.8 | 8.2 | 9.1 | 9.7
65+ | 1.7 | 1.8 | 1.9 | 1.8 | 2.2 | 1.6
Region
Northeast | 7.5 | 8.2 | 6.3 | 6.2 | 7.4 | 7.6
Midwest | 9.4 | 9.4 | 9.0 | 9.0 | 9.3 | 9.1
South | 7.8 | 7.6 | 7.1 | 7.0 | 7.7 | 7.9
West | 10.6 | 10.5 | 10.4 | 10.1 | 11.1 | 10.2

Source: Agency for Healthcare Research and Quality, Center for Financing, Access and Cost Trends, Medical Expenditure Panel Survey, Household Component, 2003-2018.