# STATISTICAL BRIEF #488 The Uninsured in America: Estimates of the Percentage of Non-Elderly Adults Uninsured throughout Each Calendar Year, by Selected Population Subgroups and State Medicaid Expansion Status: 2013 and 2014

## Highlights

- The percentage of non-elderly adults ages 18-64, uninsured for the entire calendar year ("the uninsured rate") declined from 18.8 percent (35.6 million adults) to 14.4 percent (27.4 million adults) between 2013 and 2014.
- The uninsured rate declined between 2013 and 2014 for adults ages 18-35, 36-54, and 55-64 in both Medicaid expansion and non-expansion states. In states that expanded Medicaid, the decline was larger for adults ages 18-35, than for adults ages 55-64, narrowing the percentage point difference in the uninsured rates between these two age groups in 2014.
- Uninsured rates declined between 2013 and 2014 for Hispanic, white, black and Asian non-elderly adults ages 18-64. The percentage point difference in the uninsured rates for Hispanic non-elderly adults and white non-Hispanic adults decreased between 2013 and 2014, overall and in Medicaid expansion states.

## Introduction

The 2014 implementation of key provisions included in the Affordable Care Act (ACA) represents one of the largest health insurance expansions since the creation of Medicare and Medicaid in 1965. These provisions include premium tax credits for the purchase of private insurance for low-income adults and, in participating states, expanded Medicaid eligibility for adults with incomes up to 138 percent of the federal poverty level. Though the ACA's Medicaid expansion is optional, 26 states and the District of Columbia had expanded their Medicaid programs by the end of 2014.

Using information from the Household Component of the Medical Expenditure Panel Survey (MEPS-HC), this Brief provides annual estimates for 2009 - 2014 of the percentage and number of non-elderly adults ages 18 - 64, in the U.S. civilian noninstitutionalized population, that were uninsured for the entire calendar year. However, the primary focus of this Brief is to examine changes in calendar-year uninsured rates between 2013 and 2014 for various demographic groups, overall and by state Medicaid expansion status. All differences between estimates discussed in the text are statistically significant at the 0.05 level unless otherwise noted.

## Findings

Year-to-year changes in calendar-year uninsured rates for non-elderly adults were not significant between 2009 and 2013. However, in 2014, when key provisions of the ACA were implemented, the uninsured rate for non-elderly adults declined from the 2013 rate of 18.8 percent (35.6 million adults) to 14.4 percent (27.4 million adults) (Figure 1).The remainder of this Brief examines changes in the calendar-year uninsured rate between 2013 and 2014 for various demographic groups and by state Medicaid expansion status.

### Age

Nationally, the percentage of non-elderly adults uninsured throughout 2013 declined with increasing age (Figure 2). For example, 22.5, 18.3, and 13.2 percent of adults ages 18 - 35, 36 - 54, and 55 - 64, respectively, were uninsured throughout 2013. In 2014, uninsured rates decreased from their 2013 levels in all age groups by about 3 - 5 percentage points.

The percentage of non-elderly adults uninsured throughout 2013 also declined with age in both Medicaid expansion and non-expansion states. However, uninsured rates were lower in expansion than non-expansion states for adults in all age categories in 2013. For example, in 2013, 19.9 and 10.8 percent of adults ages 18 - 35 and 55 - 64 were uninsured in expansion states, while 25.7 percent and 16.3 percent of their counterparts in non-expansion states were uninsured, respectively.

Although uninsured rates declined for adults in all age groups in 2014 in both expansion and non-expansion states, uninsured rates continued to decrease with age, nationally and in both state categories in 2014. However, in expansion states, the decline in uninsured rates was larger for adults ages 18 - 35 (6.2 percentage points), than for those ages 55 - 64 (3.0 percentage points), narrowing the percentage point difference in uninsured rates between these two age groups.

### Race/ethnicity/nativity

In 2013, white non-Hispanic adults had a lower uninsured rate than Hispanic, black non-Hispanic and Asian non-Hispanic adults (13.2 percent for white non-Hispanic adults, 24.9 percent for Hispanic adults born in the U.S., 51.1 percent for Hispanic adults not born in the U.S., 21.1 percent for black non-Hispanic adults, and 17.4 percent for Asian non-Hispanic adults) (Figure 3).In 2014, uninsured rates declined for Hispanic, black non-Hispanic, white non-Hispanic and Asian non-Hispanic non-elderly adults. The decline for Asian non-Hispanic adults was larger than that for white non-Hispanic adults (p < 0.10), so that by 2014 there was no statistically significant percentage point difference in uninsured rates for adults in these two racial/ethnic groups. The difference in percentage points between uninsured rates for Hispanic adults born in the U.S. and white non-Hispanic adults also narrowed in 2014 (from 11.7 percentage points in 2013 to 7.7 percentage points) and the percentage point gap between Hispanic adults not born in the U.S. and white non-Hispanic adults narrowed slightly but remained large.

Similar to findings for all states, uninsured rates declined for Hispanic, white non-Hispanic, black non-Hispanic and Asian non-Hispanic adults in expansion and non-expansion states. The narrowing of the difference in uninsured rates for Hispanic non-elderly adults that were both born and not born in the U.S. and white non-Hispanic adults, described above, occurred only in expansion states.

### Sex

Uninsured rates for non-elderly men were higher than for women, both overall and in Medicaid expansion and non-expansion states in both 2013 and 2014 (Figure 4). In 2014, uninsured rates declined for both men and women (21.6 to 16.8 percent for men and 16.1 to 12.0 percent for women). In Medicaid expansion states, uninsured rates declined from 19.5 to 14.0 percent for men and from 13.2 to 8.5 percent for women. In non-expansion states, rates declined from 24.2 percent to 20.2 percent for men and 19.8 percent to 16.2 percent for women.

### Educational attainment

Nationally in 2013, uninsured rates were lower for adults with higher levels of educational attainment (Figure 5). In 2013, uninsured rates were 37.4, 24.7, 17.9, and 6.3 percent for individuals with no high school diploma, a high school diploma or GED, some college, and a college degree or more, respectively. In 2014, uninsured rates declined for all education categories but the decline was smaller among those with the highest educational attainment compared to those in other education categories, narrowing the differences between those with less educational attainment and those with a college degree or more.

Uninsured rates were significantly lower in states that expanded Medicaid than in non-expansion states for non-elderly adults in each education category in 2013 and for all but the highest educational category in 2014. There was a significant decrease in 2014 for adults in all education groups in both state categories, except for adults with the highest educational attainment in expansion states. Analogous to the finding for all states, differences in uninsured rates between those with a college degree or more and those with less educational attainment narrowed in expansion states in 2014 and narrowed in non-expansion states between those with some college and a college degree or more.

## Data Source

The estimates shown in this Statistical Brief are drawn from analyses conducted by the MEPS staff from files HC-129, HC-138, HC-147, HC-155, HC-163, and HC-165, augmented with information on the person's state of residence and weighted using a weight that is post-stratified by poverty status to the Current Population Survey.

## Definitions

### Age

People were included in the sample if they were between the ages of 18 and 64 throughout the calendar year and present in the MEPS-HC for the entire calendar year. This restriction excludes individuals who were institutionalized, left the country or died during the year and those who joined the household after January. Age is categorized based on the person's age at the end of the calendar year.

### Uninsured

People who did not have health insurance coverage for the entire calendar year were classified as uninsured. The uninsured were defined as people not covered by Medicaid, Medicare, TRICARE (Armed Forces-related coverage), other public hospital/physician programs, private hospital/physician insurance (including Medigap coverage) or insurance purchased through health insurance Marketplaces established in accordance with the Affordable Care Act. People covered only by non-comprehensive State-specific programs (e.g., Maryland Kidney Disease Program) or private single service plans such as coverage for dental or vision care only, or coverage for accidents or specific diseases, were considered uninsured.

### Race/ethnicity/nativity

Classification by race/ethnicity was based on information reported for each family member. First, respondents were asked if the person's main national origin or ancestry was Puerto Rican; Cuban; Mexican, Mexican-American, or Chicano; other Latin American; or other Spanish. All persons whose main national origin or ancestry was reported in one of these Hispanic groups, regardless of racial background, were classified as Hispanic. All other persons were classified according to their reported race. For this analysis, the following classification by race/ethnicity, in combination with information on nativity, was used: Hispanic adults who were born in the U.S. (of any race), Hispanic adults who were not born in the U.S. (of any race), black non-Hispanic only, white non-Hispanic only, Asian non-Hispanic only, and other non-Hispanic or multiple races reported.

### Education

Information on the highest level of schooling completed or the highest degree received by a person was asked in the first round the person was included in the MEPS-HC. The categories included in this Statistical Brief include 12 or fewer years of school (no high school diploma), high school diploma or GED, some college, and a college degree or more.

### Medicaid expansion states

This analysis defined Medicaid expansion states as those states that implemented the ACA's Medicaid expansion at any time during calendar year 2014 and this definition was used to classify states in 2013 as well as in 2014. Medicaid expansion states included Arizona, Arkansas, California, Colorado, Connecticut, Delaware, District of Columbia, Hawaii, Illinois, Iowa, Kentucky, Maryland, Massachusetts, Michigan, Minnesota, Nevada, New Hampshire, New Jersey, New Mexico, New York, North Dakota, Ohio, Oregon, Rhode Island, Vermont, Washington, and West Virginia.

## About MEPS-IC

MEPS-HC is a nationally representative longitudinal survey that collects detailed information on health care utilization and expenditures, health insurance, and health status, as well as a wide variety of social, demographic, and economic characteristics for the U.S. civilian noninstitutionalized population. It is co-sponsored by the Agency for Healthcare Research and Quality and the National Center for Health Statistics. For more information about MEPS, call the MEPS information coordinator at AHRQ (301) 427-1406 or visit the MEPS Web site at http://www.meps.ahrq.gov/.

## References

Carroll W. (2013). The Uninsured in America, First Part of 2013: Estimates for the U.S. Civilian Noninstitutionalized Population under Age 65.
Cohen J. (1997). Design and Methods of the Medical Expenditure Panel Survey Household Component.
Ezzati-Rice T.M., Rohde F., Greenblatt J. (2008). Sample Design of the Medical Expenditure Panel Survey Household Component, 1998-2007.
Kaiser Family Foundation. Status of State Action on the Medicaid Expansion Decision. Kaiser Family Foundation, 2016.
Rhoades J.A., Cohen S.B. (2013). The Long-Term Uninsured in America, 2008-2011 (Selected Intervals): Estimates for the U.S. Civilian Noninstitutionalized Population under Age 65.
Roemer M. (2013). The Uninsured in America, First Part of 2012: Estimates for the U.S. Civilian Noninstitutionalized Population under Age 65.
Vistnes J., Lipton B., Miller G.E. (2016). Uninsurance and Insurance Transitions Before and After 2014: Estimates for U.S., Non-Elderly Adults by Health Status, Presence of Chronic Conditions and State Medicaid Expansion Status.
Vistnes J., Miller G.E. (2016). Transitions in Health Insurance Coverage for Non-Elderly Adults in the U.S. Civilian Noninstitutionalized Population: 2013-2014 and Selected Preceding Two-Year Periods.

## Suggested Citation

Vistnes, J. and Lipton, B. The Uninsured in America: Estimates of the Percentage of Non-Elderly Adults Uninsured throughout Each Calendar Year, by Selected Population Subgroups and State Medicaid Expansion Status: 2013 and 2014. Statistical Brief #488. June 2016. Agency for Healthcare Research and Quality, Rockville, MD. http://meps.ahrq.gov/mepsweb/data_files/publications/st488/stat488.pdf

AHRQ welcomes questions and comments from readers of this publication who are interested in obtaining more information about access, cost, use, financing, and quality of health care in the United States. We also invite you to tell us how you are using this Statistical Brief and other MEPS data and tools and to share suggestions on how MEPS products might be enhanced to further meet your needs. Please email us at MEPSProjectDirector@ahrq.hhs.gov or send a letter to the address below:

Joel W. Cohen, PhD, Director
Center for Financing, Access, and Cost Trends
Agency for Healthcare Research and Quality
5600 Fishers Lane, Mailstop 07W41A
Rockville, MD 20857

Figure 1 Non-elderly adults ages 18-64, uninsured for the entire calendar year or with insurance at some point in the calendar year, 2009-2014

| Population in millions | | Percentage of adults ages 18-64
| Uninsured | Insured | Uninsured
2009 | 35.5 | 150.2 | 19.1
2010 | 34.3 | 152.1 | 18.4
2011 | 33.4 | 154.3 | 17.8
2012 | 34.9 | 153.6 | 18.5
2013 | 35.6 | 153.8 | 18.8
2014 | 27.4 | 163.5 | 14.4

Source: Medical Expenditure Panel Survey - Household Component, 2009-2014

Figure 2 Percentage of non-elderly adults ages 18-64, who were uninsured for the entire calendar year, by age and state Medicaid expansion status, 2013 and 2014

| Total uninsured | | Medicaid expansion states | | Non-expansion states
| 2013 | 2014 | 2013 | 2014 | 2013 | 2014
Ages 18-35 | 22.5% | 17.6% | 19.9% | 13.7% | 25.7% | 22.3%
Ages 36-54 | 18.3% | 13.6% | 15.7% | 10.5% | 21.4% | 17.4%
Ages 55-64 | 13.2% | 10.0% | 10.8% | 7.8% | 16.3% | 12.7%

Source: Medical Expenditure Panel Survey - Household Component, 2013-2014

Figure 3 Percentage of non-elderly adults ages 18 to 64, who were uninsured for the entire calendar year, by race/ethnicity/nativity and state Medicaid expansion status, 2013 and 2014

| Total uninsured | | Medicaid expansion states | | Non-expansion states
| 2013 | 2014 | 2013 | 2014 | 2013 | 2014
Hispanic born in U.S. | 24.9% | 17.0% | 21.7% | 13.2% | 29.5% | 22.8%
Hispanic not born in U.S. | 51.1% | 43.8% | 46.9% | 38.1% | 57.0% | 51.6%
Non-Hispanic white | 13.2% | 9.3% | 10.8% | 6.6% | 16.2% | 12.5%
Non-Hispanic black | 21.1% | 17.2% | 18.8% | 13.3% | 22.7% | 19.7%
Asian | 17.4% | 10.8% | 15.0% | 8.8% | 24.1% | 17.0%
Other | 13.1% | 13.1% | 10.6% | 6.9% | 17.3% | 21.1%

Source: Medical Expenditure Panel Survey - Household Component, 2013-2014

Figure 4 Percentage of non-elderly adults ages 18 to 64, who were uninsured for the entire calendar year, by sex and state Medicaid expansion status, 2013 and 2014

| Total uninsured | | Medicaid expansion states | | Non-expansion states
| 2013 | 2014 | 2013 | 2014 | 2013 | 2014
Men | 21.6% | 16.8% | 19.5% | 14.0% | 24.2% | 20.2%
Women | 16.1% | 12.0% | 13.2% | 8.5% | 19.8% | 16.2%

Source: Medical Expenditure Panel Survey - Household Component, 2013-2014

Figure 5 Percentage of non-elderly adults ages 18 to 64, who were uninsured for the entire calendar year, by race/ethnicity/nativity and state Medicaid expansion status, 2013 and 2014

| Total uninsured | | Medicaid expansion states | | Non-expansion states
| 2013 | 2014 | 2013 | 2014 | 2013 | 2014
No HS diploma | 37.4% | 31.6% | 33.5% | 25.8% | 42.2% | 38.6%
HS diploma/GED | 24.7% | 19.7% | 21.8% | 14.9% | 27.6% | 24.3%
Some college | 17.9% | 12.3% | 16.1% | 9.7% | 20.1% | 15.4%
College degree or more | 6.3% | 4.9% | 5.2% | 4.3% | 7.8% | 5.8%

Source: Medical Expenditure Panel Survey - Household Component, 2013-2014