# STATISTICAL BRIEF #480 Differentials in the Concentration of Health Expenditures across Population Subgroups in the U.S., 2013

## Highlights

- In 2013, the top 1 percent ranked by their health care expenses accounted for 21.5 percent of total health care expenditures with an annual mean expenditure of $95,200.
- Overall, the top 50 percent of the population ranked by their expenditures accounted for 97.1 percent of overall health care expenditures, while the lower 50 percent accounted for only 2.9 percent of the total.
- Individuals age 65 and older were characterized by substantially less concentrated levels of health care spending relative to their younger counterparts. Alternatively, the elderly had the highest mean levels of health care expenditures relative to younger population subgroups at the top quantiles of the expenditure distribution.
- The top 5 percent of the uninsured population under age 65 ranked by their health care expenses accounted for 67.5 percent of the health care expenditures incurred by this subpopulation with an annual mean of $17,902
- Conditioned on insurance coverage status, the uninsured had the lowest annual mean expenses.
- For Hispanics, the top five percent accounted for 57.3 percent of their health care expenditures with an annual mean of $28,868. Alternatively, non-Hispanic whites and other races and black non-Hispanics exhibited higher mean levels of health care expenditures than Hispanics and non-Hispanic Asians at the top quantiles of the expenditure distribution.

## Introduction

Estimates of health care expenses for the U.S. civilian noninstitutionalized (community) population are critical to policymakers and others concerned with access to medical care and the cost and sources of payment for that care. In 2013, health care expenses among the U.S. community population totaled $1.40 trillion, with a mean expenditure per person of $4,436 (data not shown). Medical care expenses, however, are highly concentrated among a relatively small proportion of individuals in the community population. As previously reported in 1996, the top 1 percent of the U.S. population accounted for 28 percent of the total health care expenditures and the top 5 percent for more than half. More recent data have revealed that over time there has been some decrease in the extent of this concentration at the upper tail of the expenditure distribution.

Using information from the Household Component of the Medical Expenditure Panel Survey (MEPS-HC) for 2013, this Brief provides detailed estimates of the concentration in the level of health care expenditures for the nation, and further distinguished by specific population subgroups. Studies that examine the concentration of health care expenditures, their magnitude, and their respective differentials distinguished by specific population subgroups are essential to helping discern the factors most likely to drive health care spending and the characteristics of the individuals who incur them. The MEPS-HC data are particularly well suited for measuring the population's distribution of health care expenditures. All differences between estimates discussed in the text are statistically significant at the 0.05 level unless otherwise noted.

## Findings

In 2013, the top 1 percent of persons ranked by their health care expenses accounted for 21.5 percent of total health care expenditures with an annual mean expenditure of $95,200 (Figure 1). The top 5 percent of the population accounted for 48.7 percent of total expenditures with an annual mean expenditure of $43,253. In addition, the top 10 percent of the population accounted for 64.9 percent of total expenditures with an annual mean expenditure of $28,808. Overall, the top 50 percent of the population ranked by their expenditures accounted for 97.1 percent of overall health care expenditures, while the lower 50 percent accounted for only 2.9 percent of the total. Those individuals ranked in the top half of the health care expenditure distribution had an annual mean expenditure of $8,619.

### Age

In 2013, the top 5 percent of children under the age of 18 ranked by their health care expenses accounted for 56.1 percent of the health care expenditures incurred by this subpopulation with an annual mean expenditure of $22,632 (Figure 2). Among persons 18 -44, the top 5 percent accounted for 52.6 percent of the health care expenditures incurred by this population subgroup with an annual mean of $29,014. The top 5 percent of individuals 45 -64 were associated with 45.6 percent of the health care expenditures incurred by this age group with an annual mean of $54,033. Alternatively, the top 5 percent of the elderly age 65 and older accounted for 32.6 percent of the medical expenditures experienced by this domain, with an annual mean of $63,320. In summary, the oldest age cohort was characterized by the least concentrated levels of health care spending relative to their younger counterparts. In contrast, the elderly had the highest mean levels of health care expenditures relative to younger population subgroups at the highest quantiles of the health care expenditure distribution.

### Race/ethnicity

The top 5 percent of non-Hispanic whites and other races accounted for 45.3 percent of the health care expenditures incurred by this subpopulation with an annual mean of $46,809 in 2013 (Figure 3). Among non-Hispanic black individuals, the top 5 percent accounted for 56.3 percent of the health care expenditures for this subgroup, with an annual mean of $45,574. For non-Hispanic Asians, the top 5 percent were associated with 50.8 percent of the health care expenditures incurred for this subpopulation, exhibiting a mean of $26,491. For Hispanics, the top five percent accounted for 57.3 percent of their health care expenditures with an annual mean of $28,868. Non-Hispanic whites/other races had lower concentrations of expenditures than their Hispanic and non-Hispanic black counterparts at the higher tiers. Alternatively, non-Hispanic whites and other races and blacks exhibited higher mean levels of health care expenditures than Hispanics and non-Hispanic Asians at the top quantiles of the expenditure distribution.

### Sex

In 2013, the top 5 percent of males accounted for 52.6 percent of health care expenditures incurred by this subpopulation with an annual mean of $40,939 (Figure 4)). Among females, the top 5 percent were associated with 45.5 percent of health care expenditures for this subgroup, with mean expenditures of $45,071. Conditioned on sex, males had a more concentrated level of health care expenditures.

### Insurance status

The top 5 percent of the uninsured population under age 65 ranked by their health care expenses accounted for 67.5 percent of the health care expenditures incurred by this subpopulation with an annual mean of $17,902 in 2013 (Figure 5). Among non-elderly persons with public coverage only, the top 5 percent accounted for 55.0 percent of health care expenditures for this subgroup, with mean expenditures of $44,438. For those non-elderly with any private coverage, the top 5 percent were associated with 49.3 percent of this group's overall health care expenses, exhibiting a mean of $38,455. The privately and publicly insured under age 65 had lower concentrated levels of health care expenditures, while the uninsured had the lowest annual mean expenses at the top quantiles of the expenditure distribution.

### Income

In 2013, the top 5 percent of the poor accounted for 53.2 percent of health care expenditures incurred by this subgroup with an annual mean of $43,066 (Figure 6). For near poor individuals, the top 5 percent were associated with 49.8 percent of health care expenses for this subpopulation, exhibiting a mean of $46,658. Among low income persons, the top 5 percent accounted for 49.6 percent of this group's overall health care expenditures, with an annual mean of $41,456. The top 5 percent of the middle income subgroup accounted for 52.2 percent of health care expenditures and an annual mean of $46,920. For those persons in the high income subgroup, the top 5 percent were associated with 43.8 percent of health care expenditures, exhibiting a mean of $40,512.

## Data Source

The estimates shown in this Statistical Brief are drawn from analyses conducted by the MEPS staff from the following public use files: MEPS HC-155 and HC-163, the 2012 and 2013 Full Year Consolidated Data Files; and the MEPS Panel 17 Longitudinal Data File.

## Definitions

### Expenditures

MEPS-HC defines total expense as the sum of payments from all sources to hospitals, physicians, other health care providers (including dental care), and pharmacies for services reported by respondents in the MEPS-HC. Sources include direct payments from individuals and families, private insurance, Medicare, Medicaid, and miscellaneous other sources.

### Age

Age was defined as age at the end of the year 2013.

### Race/ethnicity

Classification by race and ethnicity was based on information reported for each family member. Respondents were asked if each family member's race was best described as American Indian, Alaska Native, Asian or Pacific Islander, black, white, or other. They also were asked if each family member's main national origin or ancestry was Puerto Rican; Cuban; Mexican, Mexicano, Mexican American, or Chicano; other Latin American; or other Spanish. All persons whose main national origin or ancestry was reported in one of these Hispanic groups, regardless of racial background, were classified as Hispanic. Since the Hispanic grouping can include black Hispanic, white Hispanic, Asian and Pacific Islanders Hispanic, and other Hispanic, the race categories of black, white, Asian and Pacific Islanders, and other only include non-Hispanics for the race/ethnicity classifications. MEPS respondents who reported other single or multiple races and were non-Hispanic were included in the other category. For this analysis, the following classification by race and ethnicity was used: Hispanic (of any race), non-Hispanic blacks single race, non-Hispanic whites single race, and others, and non-Hispanic Asian and Pacific Islanders single race.

### Health insurance status

Individuals under age 65 were classified into the following three insurance categories based on household responses to the health insurance status questions:

- Any private health insurance: Individuals who, at any time during the year, had insurance that provided coverage for hospital and physician care (other than Medicare, Medicaid, or other public hospital/physician coverage) were classified as having private insurance. Coverage by TRICARE (Armed Forces-related coverage) was also included as private health insurance. Insurance that provided coverage for a single service only, such as dental or vision coverage, was not included.
- Public coverage only: Individuals were considered to have public coverage only if they met both of the following criteria: 1) they were not covered by private insurance at any time during the year, and 2) they were covered by one of the following public programs at some point during the year: Medicare, Medicaid, or other public hospital/physician coverage.
- Uninsured: The uninsured were defined as people not covered by private hospital/physician insurance, Medicare, TRICARE, Medicaid, or other public-hospital /physician programs at any time during the entire year or their period of eligibility for the survey.

### Income

Sample persons were classified according to the total yearly income of their family. Within a household, all people related by blood, marriage, or adoption were considered to be a family. Poverty status categories are defined by the ratio of family income to the federal income thresholds, which control for family size and age of the head of family. Poverty status was based on annual income in 2013.

Poverty status categories are defined as follows:

- Poor: Persons in families with income less than or equal to the poverty line; includes those who had negative income.
- Near poor: Persons in families with income over the poverty line through 125 percent of the poverty line.
- Low income: Persons in families with income over 125 percent through 200 percent of the poverty line.
- Middle income: Persons in families with income over 200 percent through 400 percent of the poverty line.
- High income: Persons in families with income over 400 percent of the poverty line.

## About MEPS-HC

MEPS-HC is a nationally representative longitudinal survey that collects detailed information on health care utilization and expenditures, health insurance, and health status, as well as a wide variety of social, demographic, and economic characteristics for the U.S. civilian noninstitutionalized population. It is cosponsored by the Agency for Healthcare Research and Quality and the National Center for Health Statistics.

For more information about MEPS, call the MEPS information coordinator at AHRQ (301-427-1406) or visit the MEPS Web site at ( http://www.meps.ahrq.gov/).

## References

For a detailed description of the MEPS survey design, sample design, and methods used to minimize sources of nonsampling error, see the following publications:

Cohen J. (1997). Design and Methods of the Medical Expenditure Panel Survey Household Component.
Cohen, S. Design Strategies and Innovations in the Medical Expenditure Panel Survey. Medical Care, July 2003: 41(7) Supplement: III-5-III-12.
Cohen S. (2014). Differentials in the Concentration of Health Expenditures across Population Subgroups in the U.S., 2012.
Cohen S., Uberoi N. (2013). Differentials in the Concentration in the Level of Health Expenditures across Population Subgroups in the U.S., 2010.
Ezzati-Rice T.M., Rohde F., Greenblatt J. (2008). Sample Design of the Medical Expenditure Panel Survey Household Component, 1998-2007.
Yu W., Ezzati-Rice T. (2005). Concentration of Health Care Expenditures in the U.S. Civilian Noninstitutionalized Population.

## Suggested Citation

Cohen, S. Differentials in the Concentration of Health Expenditures across Population Subgroups in the U.S., 2013. Statistical Brief #480. September 2015. Agency for Healthcare Research and Quality, Rockville, MD. http://meps.ahrq.gov/mepsweb/data_files/publications/st480/stat480.pdf

AHRQ welcomes questions and comments from readers of this publication who are interested in obtaining more information about access, cost, use, financing, and quality of health care in the United States. We also invite you to tell us how you are using this Statistical Brief and other MEPS data and tools and to share suggestions on how MEPS products might be enhanced to further meet your needs. Please email us at MEPSProjectDirector@ahrq.hhs.gov or send a letter to the address below:

Steven B. Cohen, PhD, Director
Center for Financing, Access, and Cost Trends
Agency for Healthcare Research and Quality
540 Gaither Road
Rockville, MD 20850

Figure 1 Distribution of health expenditures for the U.S. population by magnitude of expenditure and mean expenditures, 2013

| Top 1% | Top 5% | Top 15% | Top 25% | Top 50%
Health expenditures | 21.5% | 48.7% | 64.9% | 86.3% | 97.1%
Mean expenditures | $95,200 | $43,253 | $28,808 | $15,313 | $8,619

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, HC-155 and HC-163 (Panel 17, 2012-2013)

Figure 2 Distribution of health care expenditures and mean expenditures for the U.S. population by age, 2013

| Figure 2a. Distribution of health care expenditures by age | | | | Figure 2b. Annual mean expenditures by age
| Top 5% | Top 10% | Top 25% | Top 50% | Top 5% | Top 10% | Top 25% | Top 50%
0-17 | 56.1% | 68.5% | 85.4% | 96.8% | $22,632 | $13,827 | $6,877 | $3,858
18-44 | 52.6% | 69.5% | 88.7% | 98.0% | $29,014 | $19,131 | $9,775 | $5,402
45-64 | 45.6% | 61.0% | 83.2% | 95.9% | $54,033 | $36,384 | $19,749 | $11,379
65+ | 32.6% | 47.8% | 72.5% | 90.8% | $63,320 | $46,317 | $28,104 | $17,594

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, HC-155 and HC-163 (Panel 17, 2012-2013)

Figure 3 Distribution of health care expenditures and mean expenditures for the U.S. population by race/ethnicity, 2013

| Figure 3a. Distribution of health care expenditures by race/ethnicity | | | | Figure 3b. Annual mean expenditures by race/ethnicity
| Top 5% | Top 10% | Top 25% | Top 50% | Top 5% | Top 10% | Top 25% | Top 50%
White non-Hispanic | 45.3% | 61.4% | 83.7% | 96.1% | $46,809 | $31,741 | $17,294 | $9,932
Black non-Hispanic | 56.3% | 72.3% | 90.5% | 98.3% | $45,574 | $29,069 | $14,539 | $7,900
Asian non-Hispanic | 50.8% | 67.6% | 87.7% | 97.8% | $26,491 | $17,576 | $9,147 | $5,087
Hispanic | 57.3% | 73.7% | 91.2% | 98.5% | $28,868 | $18,578 | $9,191 | $4,961

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, HC-155 and HC-163 (Panel 17, 2012-2013)

Figure 4 Distribution of health care expenditures and mean expenditures for the U.S. population by sex, 2013

| Figure 4a. Distribution of health care expenditures by sex | | | | Figure 4b. Annual mean expenditures by sex
| Top 5% | Top 10% | Top 25% | Top 50% | Top 5% | Top 10% | Top 25% | Top 50%
Male | 52.6% | 68.8% | 88.6% | 97.9% | $40,939 | $26,814 | $13,797 | $7,624
Female | 45.5% | 61.6% | 84.0% | 96.2% | $45,071 | $30,543 | $16,640 | $9,537

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, HC-155 and HC-163 (Panel 17, 2012-2013)

Figure 5 Distribution of health care expenditures and mean expenditures for the U.S. population by insurance coverage status, 2013

| Figure 5a. Distribution of health care expenditures by insurance coverage status | | | | Figure 5b. Annual mean expenditures by insurance coverage status
| Top 5% | Top 10% | Top 25% | Top 50% | Top 5% | Top 10% | Top 25% | Top 50%
Uninsured | 67.5% | 81.1% | 95.1% | 99.9% | $17,902 | $10,778 | $5,045 | $2,647
Public insurance | 55.0% | 71.3% | 90.4% | 98.1% | $44,438 | $28,663 | $14,520 | $7,881
Private insurance | 49.3% | 64.7% | 84.7% | 96.0% | $38,455 | $25,169 | $13,189 | $7,476

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, HC-155 and HC-163 (Panel 17, 2012-2013)

Figure 6 Distribution of health care expenditures and mean expenditures for the U.S. population by income, 2013

| Figure 6a. Distribution of health care expenditures by income | | | | Figure 6b. Annual mean expenditures by income
| Top 5% | Top 10% | Top 25% | Top 50% | Top 5% | Top 10% | Top 25% | Top 50%
Poor | 53.2% | 70.4% | 90.6% | 98.5% | $43,066 | $28,515 | $14,671 | $7,980
Near poor | 49.8% | 67.7% | 89.9% | 98.5% | $46,658 | $31,814 | $16,857 | $9,223
Low income | 49.6% | 67.8% | 89.4% | 98.2% | $41,456 | $28,298 | $14,926 | $8,198
Middle income | 52.2% | 67.4% | 87.5% | 97.4% | $46,920 | $30,260 | $15,715 | $8,747
High income | 43.8% | 59.5% | 81.8% | 95.2% | $40,512 | $27,510 | $15,119 | $8,797

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, HC-155 and HC-163 (Panel 17, 2012-2013)