# STATISTICAL BRIEF #457 National Health Care Expenses Per Person in the U.S. Civilian Noninstitutionalized Population, 2012

## Highlights

- In 2012, the proportion of persons with expenses varied widely by type of service, with large proportions having expenses for ambulatory services (74.9 percent) and prescribed medicines (62.4 percent) and much smaller proportions having expenses for home health care and other medical equipment (18.0 percent) and hospital inpatient services (7.2 percent).
- Overall, the mean and median expenses of persons with any health care expenses in 2012 (84.7 percent of the population) were $5,089 and $1,285, respectively.
- Mean expenses for persons age 65 and older with an expense ($9,678) were more than twice the amount for persons under age 65 ($4,186).

## Introduction

This Statistical Brief presents estimates of the percentage of persons with a health care expense by type of service, and average and median expense per person with an expense by age and insurance status for the U.S. civilian noninstitutionalized population in 2012. Health care expenses, as reported in this Brief, represent payments to hospitals, physicians, and other health care providers based on utilization information collected in the Medical Expenditure Panel Survey (MEPS) Household Component and payment data collected in both the MEPS Household and Medical Provider Components. Expense estimates include amounts paid by individuals, private insurance, Medicare, Medicaid, and other payment sources. All differences between estimates discussed in the text are statistically significant at the 0.05 level.

## Findings

In 2012, 84.7 percent of the U.S. civilian noninstitutionalized population (about 265.5 million persons) had some expenses for health care which includes hospital inpatient, ambulatory services (office-based visits, hospital outpatient care, and emergency room services), prescribed medicines, dental services, and home health care and other medical services and equipment (Figure 1)^1^. he proportion of people with expenses varied widely by type of service, with large proportions having expenses for ambulatory services (74.9 percent) and prescribed medicines (62.4 percent) and much smaller proportions having expenses for home health care and other medical services (18.0 percent), and hospital inpatient services (7.2 percent). Across all service categories, a larger percentage of persons age 65 and older had expenses compared to persons under age 65 for: hospital inpatient services (16.1 versus 5.8); ambulatory services expenses (91.8 versus 72.1); prescribed medicines (90.8 versus 57.6); dental services (43.1 versus 39.9); and home health care and other medical services and equipment (30.9 versus 15.8).

The mean total expense per person for those with some health care expenses in 2012 was $5,089 (Figure 2). Among specific health care service categories, the mean expense per person who had expenses of that type ranged from $18,012 for hospital inpatient services to $670 for dental services. Mean total expenses for persons age 65 and older with an expense ($9,678) was more than twice the amount for persons under age 65 ($4,186). Adults age 65 and older had larger mean expenses in the following service categories compared to persons under age 65: ambulatory services ($3,031 versus $1,850); prescribed medicines ($2,190 versus $1,314); dental services ($870 versus $634); and home health care and other medical services and supplies ($3,345 versus $791).

Median expenses were substantially lower than mean expenses, among health care service categories, because a relatively small proportion of persons accounts for a large proportion of expenses. The overall median total expense per person with an expense was $1,285, and ranged across service categories from $10,308 for hospital inpatient services to $242 for dental services (Figure 3). Median expenses per person with an expense of that type were consistently higher for the elderly across all service categories when compared with persons under age 65.

As shown in Figure 4, average annual health care expenses varied by age and type of health insurance coverage. Persons under age 65 with an expense had a mean total expense of $4,186 and a median total expense of $1,000, while those age 65 years and older had a mean total expense of $9,678 and a median total expense of $4,290. Among persons under age 65 with expenses, the mean expenses for those who had any private insurance ($4,407) or public only insurance ($4,402) were about twice that for the uninsured ($2,198). Among persons age 65 and older with expenses, those with Medicare only had lower mean expenses ($8,206) than those with both Medicare and other public sources of payment ($13,890).

## Data Source

The estimates in this Statistical Brief are based upon data from the MEPS HC-155: 2012 Full Year Consolidated Data File.

## Definitions

### Expenditures

Expenditures include total direct payments from all sources to hospitals, physicians, home health providers (agency and paid independent providers), dental providers, other types of health care providers (e.g., physical therapists, chiropractors, optometrists, etc.), and pharmacies for services reported by respondents in the MEPS-HC. Expenditures for hospital-based services include those for both facility and separately billed physician services.

### Health insurance status

Individuals under age 65 were classified in the following three insurance categories, based on household responses to health insurance status questions:

- Any private health insurance: Individuals who, at any time during the year, had insurance that provides coverage for hospital and physician care (other than Medicare, Medicaid/CHIP, or other public hospital/physician coverage) were classified as having private insurance. Coverage by TRICARE (Armed Forces-related coverage) was also included as private health insurance. Insurance that provides coverage for a single service only, such as dental or vision coverage, was not included.
- Public coverage only: Individuals were considered to have public coverage only if they met both of the following criteria: 1) they were not covered by private insurance at any time during the year; and 2) they were covered by any of the following public programs at any point during the year: Medicare, Medicaid/CHIP, or other public hospital/physician coverage.
- Uninsured: The uninsured were defined as people not covered by private hospital/physician insurance, Medicare, TRICARE, Medicaid/CHIP, or other public hospital/physician programs at any time during the entire year or period of eligibility for the survey.

Individuals age 65 and older were classified into the following three insurance categories:

- Medicare and private insurance: This category includes persons classified as Medicare beneficiaries and covered by Medicare and a supplementary private policy.
- Medicare and other public insurance: This category includes persons classified as Medicare beneficiaries who met both of the following criteria: 1) They were not covered by private insurance at any point during the year; and 2) They were covered by one of the following public programs at any point during the year: Medicaid, other public hospital/physician coverage.
- Medicare only: This category includes persons classified as Medicare beneficiaries but not classified as Medicare and private insurance or as Medicare and other public insurance. This group includes persons who were enrolled in Medicare Advantage (Part C) and persons who had traditional Medicare fee-for-service coverage only.

## About MEPS-HC

MEPS-HC is a nationally representative longitudinal survey that collects detailed information on health care utilization and expenditures, health insurance, and health status, as well as a wide variety of social, demographic, and economic characteristics for the U.S. civilian noninstitutionalized population. It is cosponsored by the Agency for Healthcare Research and Quality and the National Center for Health Statistics.

MEPS expenditure data are derived from both the Medical Provider Component (MPC) and Household Component (HC). MPC data are generally used for hospital-based events (e.g., inpatient stays, emergency room visits, and outpatient department visits), prescribed medicine purchases, and home health agency care. Office-based physician care estimates use a mix of HC and MPC data, while estimates for non-physician office visits, dental and vision services, other medical equipment and services, and independent provider home health care services are based on HC provided data. Details on the estimation process can be found in Machlin, S.R. and Dougherty, D.D. Overview of Methodology for Imputing Missing Expenditure Data in the Medical Expenditure Panel Survey. Methodology Report No. 19. March 2007. Agency for Healthcare Research and Quality, Rockville, MD. http://www.meps.ahrq.gov/mepsweb/data_files/publications/mr19/mr19.pdf

For more information about MEPS, call the MEPS information coordinator at AHRQ (301-427-1656) or visit the MEPS Web site at http://www.meps.ahrq.gov/.

## References

For a detailed description of the MEPS-HC survey design, sample design, and methods used to minimize sources of non-sampling errors, see the following publications:

Cohen, J. (1997). Design and Methods of the Medical Expenditure Panel Survey Household Component.
Cohen, S. (1997). Sample Design of the 1996 Medical Expenditure Panel Survey Household Component.
Cohen, S. Design Strategies and Innovations in the Medical Expenditure Panel Survey. Medical Care, July 2003: 41(7) Supplement: III-5-III-12. 12865722
Ezzati-Rice, T.M., Rohde, F., Greenblatt, J. (2008). Sample Design of the Medical Expenditure Panel Survey Household Component, 1998-2007.

## Suggested Citation

Carper, K. and Stagnitti, M.N. National Health Care Expenses Per Person in the U.S. Civilian Noninstitutionalized Population, 2012. Statistical Brief #457. November 2014. Agency for Healthcare Research and Quality, Rockville, MD. http://www.meps.ahrq.gov/mepsweb/data_files/publications/st457/stat457.pdf

AHRQ welcomes questions and comments from readers of this publication who are interested in obtaining more information about access, cost, use, financing, and quality of health care in the United States. We also invite you to tell us how you are using this Statistical Brief and other MEPS data and tools and to share suggestions on how MEPS products might be enhanced to further meet your needs. Please email us at MEPSProjectDirector@hhs.ahrq.gov or send a letter to the address below:

Steven B. Cohen, PhD, Director
Center for Financing, Access, and Cost Trends
Agency for Healthcare Research and Quality
540 Gaither Road
Rockville, MD 20850

1 Of the 15.3 percent of the population with no health care expenses, a very small proportion actually received health services for which no direct payments were made.

Figure 1 Percentage of persons with health care expenses, by type of service, 2012

| Total | <65 years | 65+ years
Any services | 84.7% | 82.7% | 96.3%
Hospital inpatient services | 7.2% | 5.8% | 16.1%
Ambulatory services | 74.9% | 72.1% | 91.8%
Prescribed medicines | 62.4% | 57.6% | 90.8%
Dental services | 40.4% | 39.9% | 43.1%
Home health care and other medical services and equipment | 18.0% | 15.8% | 30.9%

Note: Estimates are for the U.S. civilian noninstitutionalized population.

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2012

Figure 2 Mean expense per person with health care expenses, by type of service^a^ and age, 2012

| All ages | < 65 years | 65+ years
All services (total) | $5,089 | $4,186 | $9,678
Hospital inpatient services | $18,012 | $17,263 | $19,604
Ambulatory services | $2,059 | $1,850 | $3,031
Prescribed medicines | $1,498 | $1,314 | $2,190
Dental services | $670 | $634 | $870
Home health care and other medical services and supplies | $1,424 | $791 | $3,345

^a^Means based on persons with expenses for that service type.

Note: Estimates are for the U.S. civilian noninstitutionalized population.

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2012

Figure 3 Median expense per person with health care expenses, by type of service^a^ and age, 2012

| All ages | < 65 years | 65+ years
All services (total) | $1,285 | $1,000 | $4,290
Hospital inpatient services | $10,308 | $9,408 | $12,982
Ambulatory services | $611 | $503 | $1,385
Prescribed medicines | $252 | $171 | $961
Dental services | $242 | $230 | $329
Home health care and other medical services and supplies | $275 | $239 | $483

^a^Means based on persons with expenses for that service type.

Note: Estimates are for the U.S. civilian noninstitutionalized population.

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2012

Figure 4 Mean and median expenses for persons with health care expenses, by age and insurance status^a^, 2012

| Mean | Median
All persons | $4,186 | $1,000
Any private | $4,407 | $1,161
Public only | $4,402 | $701
Uninsured | $2,198 | $489
All persons | $9,678 | $4,290
Medicare only | $8,206 | $3,367
Medicare & private | $9,967 | $4,902
Medicare & other public | $13,890 | $5,722

^a^Means based on persons with expenses for that service type.

*A negligible number of persons age 65+ without Medicare are excluded from these estimates.

Note: Estimates are for the U.S. civilian noninstitutionalized population.

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2012