# STATISTICAL BRIEF #448 Differentials in the Concentration of Health Expenditures across Population Subgroups in the U.S., 2012

## Highlights

- In 2012, the top 1 percent ranked by their health care expenses accounted for 22.7 percent of total health care expenditures with an annual mean expenditure of $97,956. Overall, the top 50 percent of the population ranked by their expenditures accounted for 97.3 percent of overall health care expenditures, while the lower 50 percent accounted for only 2.7 percent of the total.
- Individuals age 65 and older were characterized by substantially less concentrated levels of health care spending relative to their younger counterparts. Alternatively, the elderly had the highest mean levels of health care expenditures relative to younger population subgroups at the top quantiles of the expenditure distribution.
- The top 5 percent of the uninsured population under age 65 ranked by their health care expenses accounted for 58.9 percent of the health care expenditures incurred by this subpopulation with an annual mean of $14,565. Conditioned on insurance coverage status, the uninsured had the lowest annual mean expenses.
- The top 5 percent of individuals with four or more chronic conditions accounted for 29.7 percent of health care expenditures for this subpopulation with an annual mean of $78,198. Based on chronic condition status, persons with four or more chronic conditions had the lowest concentrated levels of health care expenditures and higher annual mean expenses at the top quantiles of the expenditure distribution.

## Introduction

Estimates of health care expenses for the U.S. civilian noninstitutionalized (community) population are critical to policymakers and others concerned with access to medical care and the cost and sources of payment for that care. In 2012, health care expenses among the U.S. community population totaled $1.35 trillion. Medical care expenses, however, are highly concentrated among a relatively small proportion of individuals in the community population. As previously reported in 1996, the top 1 percent of the U.S. population accounted for 28 percent of the total health care expenditures and the top 5 percent for more than half. More recent data have revealed that over time there has been some decrease in the extent of this concentration at the upper tail of the expenditure distribution.

Using information from the Household Component of the Medical Expenditure Panel Survey (MEPS-HC) for 2012, this Brief provides detailed estimates of the concentration in the level of health care expenditures for the nation, further distinguished by specific population subgroups. Studies that examine the concentration of health care expenditures, their magnitude, and their respective differentials distinguished by specific population subgroups are essential to helping discern the factors most likely to drive health care spending and the characteristics of the individuals who incur them. The MEPS-HC data are particularly well suited for measuring the population's distribution of health care expenditures. All differences between estimates discussed in the text are statistically significant at the 0.05 level unless otherwise noted.

## Findings

In 2012, the top 1 percent ranked by their health care expenses accounted for 22.7 percent of total health care expenditures with an annual mean expenditure of $97,956 (Figure 1). The top 5 percent of the population accounted for 50.0 percent of total expenditures with an annual mean expenditure of $43,058. In addition, the top 10 percent of the population accounted for 66.0 percent of total expenditures with an annual mean expenditure of $28,468. Overall, the top 50 percent of the population ranked by their expenditures accounted for 97.3 percent of overall health care expenditures while the lower 50 percent accounted for only 2.7 percent of the total. Those individuals ranked in the top half of the health care expenditure distribution had an annual mean expenditure of $8,384.

### Age

In 2012, the top 5 percent of children under the age of 18 ranked by their health care expenses accounted for 53.8 percent of the health care expenditures incurred by this subpopulation with an annual mean expenditure of $19,520 (Figure 2). Among persons 18–44 years, the top 5 percent accounted for 52.1 percent of the health care expenditures incurred by this population subgroup with an annual mean of $27,754. The top 5 percent of individuals 45–64 were associated with 47.1 percent of the health care expenditures incurred by this age group with an annual mean of $57,030. Alternatively, the top 5 percent of the elderly aged 65 years and older accounted for 34.2 percent of the medical expenditures experienced by this domain, with an annual mean of $63,798. In summary, the oldest age cohort was characterized by the least concentrated levels of health care spending relative to their younger counterparts. In contrast, the elderly had the highest mean levels of health care expenditures relative to younger population subgroups at the highest quantiles of the health care expenditure distribution.

### Race

The top 5 percent of non-Hispanic whites and other races accounted for 45.8 percent of the health care expenditures incurred by this subpopulation with an annual mean of $46,001 in 2012 (Figure 3). Among non-Hispanic black individuals, the top 5 percent accounted for 55.2 percent of the health care expenditures for this subgroup, with an annual mean of $38,998. For non- Hispanic Asians, the top 5 percent were associated with 61.4 percent of the health care expenditures incurred for this subpopulation, exhibiting a mean of $35,681. The top 5 percent of Hispanics accounted for 62.4 percent of health care expenditures by this subpopulation with an annual mean of $32,753. Non-Hispanic whites and other race/multiple races had the lowest concentration of expenditures when controlling for race/ethnicity. Alternatively, non-Hispanic whites and other races exhibited higher mean levels of health care expenditures than Hispanics and non-Hispanic blacks at the top quantiles of the expenditure distribution.

### Sex

In 2012, the top 5 percent of males accounted for 56.0 percent of health care expenditures incurred by this subpopulation with an annual mean of $44,851 (Figure 4). Among females, the top 5 percent were associated with 44.8 percent of health care expenditures for this subgroup, with mean expenditures of $41,309. Conditioned on sex, males had a more concentrated level of health care expenditures.

### Insurance status

The top 5 percent of the uninsured population under age 65 ranked by their health care expenses accounted for 58.9 percent of the health care expenditures incurred by this subpopulation with an annual mean of $14,565 in 2012 (Figure 5). Among non-elderly persons with public coverage only, the top 5 percent accounted for 55.9 percent of health care expenditures for this subgroup, with mean expenditures of $42,355. For those non-elderly with any private coverage, the top 5 percent were associated with 51.1 percent of this group's overall health care expenses, exhibiting a mean of $39,542. Conditioned on insurance coverage status, the privately insured under age 65 had the least concentrated levels of health care expenditures while the uninsured had the lowest annual mean expenses.

### Chronic conditions

In 2012, the top 5 percent of individuals without a chronic condition accounted for 57.0 percent of health care expenditures for this subpopulation with an annual mean of $13,132 (Figure 6). For persons with a single chronic condition, the top 5 percent comprised 48.8 percent of health care expenditures incurred by this subgroup, exhibiting a mean of $31,460. Among individuals with two chronic conditions, the top 5 percent accounted for 46.9 percent of health care expenditures for this subgroup, with a mean expenditure of $53,384. For those persons with three chronic conditions, the top 5 percent were associated with 40.5 percent of this group's overall health care expenses, exhibiting a mean of $60,976. The top 5 percent of individuals with four or more chronic conditions accounted for 29.7 percent of health care expenditures for this subpopulation with an annual mean of $78,198. Based on chronic condition status, persons with four or more chronic conditions had the lowest concentrated levels of health care expenditures and the highest annual mean expenses at the top quantiles of the expenditure distribution.

### Income

In 2012, the top 5 percent of the poor accounted for 54.3 percent of health care expenditures incurred by this subgroup with an annual mean of $39,887 (Figure 7). For near poor individuals, the top 5 percent were associated with 55.3 percent of health care expenses for this subpopulation, exhibiting a mean of $58,997. Among low income persons, the top 5 percent accounted for 53.7 percent of this group's overall health care expenditures, with an annual mean of $44,893. The top 5 percent of the middle income subgroup accounted for 50.8 percent of health care expenditures and an annual mean of $41,338. For those persons in the high income subgroup, the top 5 percent were associated with 45.4 percent of health care expenditures, exhibiting a mean of $42,815. Conditioned on income, the highest income group had a significantly less concentrated level of health care expenditures than their lowest income counterparts.

## Data Source

The estimates shown in this Statistical Brief are drawn from analyses conducted by the MEPS staff from the following public use file: MEPS HC-155, 2012 Full Year Consolidated Data File.

## Definitions

### Expenditures

MEPS-HC defines total expense as the sum of payments from all sources to hospitals, physicians, other health care providers (including dental care), and pharmacies for services reported by respondents in the MEPS-HC. Sources include direct payments from individuals and families, private insurance, Medicare, Medicaid, and miscellaneous other sources.

### Age

Age was defined as age at the end of the year 2012.

### Race/ethnicity

Classification by race and ethnicity was based on information reported for each family member. Respondents were asked if each family member's race was best described as American Indian, Alaska Native, Asian or Pacific Islander, black, white, or other. They also were asked if each family member's main national origin or ancestry was Puerto Rican; Cuban; Mexican, Mexicano, Mexican American, or Chicano; other Latin American; or other Spanish. All persons whose main national origin or ancestry was reported in one of these Hispanic groups, regardless of racial background, were classified as Hispanic. Since the Hispanic grouping can include black Hispanic, white Hispanic, Asian and Pacific Islanders Hispanic, and other Hispanic, the race categories of black, white, Asian and Pacific Islanders, and other only include non-Hispanics for the race/ethnicity classifications. MEPS respondents who reported other single or multiple races and were non-Hispanic were included in the other category. For this analysis, the following classification by race and ethnicity was used: Hispanic (of any race), non-Hispanic blacks single race, non-Hispanic whites single race, and others, and non-Hispanic Asian and Pacific Islanders single race.

### Health insurance status

Individuals under age 65 were classified into the following three insurance categories based on household responses to the health insurance status questions:

- Any private health insurance: Individuals who, at any time during the year, had insurance that provided coverage for hospital and physician care (other than Medicare, Medicaid, or other public hospital/physician coverage) were classified as having private insurance. Coverage by TRICARE (Armed Forces-related coverage) was also included as private health insurance. Insurance that provided coverage for a single service only, such as dental or vision coverage, was not included.
- Public coverage only: Individuals were considered to have public coverage only if they met both of the following criteria: 1) they were not covered by private insurance at any time during the year, and 2) they were covered by one of the following public programs at some point during the year: Medicare, Medicaid, or other public hospital/physician coverage.
- Uninsured: The uninsured were defined as people not covered by private hospital/physician insurance, Medicare, TRICARE, Medicaid, or other public hospital/physician programs at any time during the entire year or their period of eligibility for the survey.

### Chronic conditions

The identification of sample persons with one or more chronic conditions was based on application of the AHRQ Healthcare Utilization Project Chronic Condition Indicator (CCI) http://www.hcup-us.ahrq.gov/toolssoftware/chronic/chronic.jsp#overview and Clinical Classification Softwarehttp://www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp tools to the MEPS medical condition files. These files contain coded information on conditions reported by MEPS respondents as being associated with medical events, disability days, and/or were bothersome during the year http://meps.ahrq.gov/mepsweb/data_stats/download_data_files_detail.jsp?cboPufNumber=HC-155. The CCI categorizes all ICD-9-CM diagnosis codes as chronic or not chronic, with chronic conditions defined as those lasting 12 months or longer that also place limitations on self-care, independent living, and social interactions or result in the need for ongoing intervention with medical products, services, and special equipment (Perrin et al., 1993). The CCI algorithm originated with work by a physician panel that reviewed diagnosis codes appearing in MEPS data (Hwang et al., 2001).

### Income

Sample persons were classified according to the total yearly income of their family. Within a household, all people related by blood, marriage, or adoption were considered to be a family. Poverty status categories are defined by the ratio of family income to the Federal income thresholds, which control for family size and age of the head of family. Poverty status was based on annual income in 2012.

Poverty status categories are defined as follows:

- Poor: Persons in families with income less than or equal to the poverty line; includes those who had negative income.
- Near poor: Persons in families with income over the poverty line through 125 percent of the poverty line.
- Low income: Persons in families with income over 125 percent through 200 percent of the poverty line.
- Middle income: Persons in families with income over 200 percent through 400 percent of the poverty line.
- High income: Persons in families with income over 400 percent of the poverty line.

## About MEPS-HC

MEPS-HC is a nationally representative longitudinal survey that collects detailed information on health care utilization and expenditures, health insurance, and health status, as well as a wide variety of social, demographic, and economic characteristics for the U.S. civilian noninstitutionalized population. It is cosponsored by the Agency for Healthcare Research and Quality and the National Center for Health Statistics.

For more information about MEPS, call the MEPS information coordinator at AHRQ (301-427-1406) or visit the MEPS Web site at http://www.meps.ahrq.gov/.

## References

Cohen, J. (1997). Design and Methods of the Medical Expenditure Panel Survey Household Component.
Cohen, S. Design Strategies and Innovations in the Medical Expenditure Panel Survey. Medical Care, July 2003: 41(7) Supplement: III-5-III-12. 12865722
Cohen, S., Uberoi, N. (2013). Differentials in the Concentration in the Level of Health Expenditures across Population Subgroups in the U.S., 2010.
Cohen, S., Yu, W. (2010). The Concentration and Persistence in the Level of Health Expenditures over Time: Estimates for the U.S. Population, 2008–2009.
Ezzati-Rice, T.M., Rohde, F., Greenblatt, J. (2008). Sample Design of the Medical Expenditure Panel Survey Household Component, 1998–2007.
Hwang, W. Weller, W. Ireys, H. Anderson, G. Out-of-Pocket Medical Spending for Care of Chronic Conditions Health Affairs, November/December 2001, 20
Perrin, E.C. Newacheck, P. Pless, I.B. Drotar, D. Gortmaker, S.L. Leventhal, J. Perrin, J.M. Stein, R.E. Walker, D.K. Weitzman, M. Issues Involved in the Definition and Classification of Chronic Health Conditions Pediatrics. 1993; 91: 787-793. 8464668
Yu, W., Ezzati-Rice, T. (2005). Concentration of Health Care Expenditures in the U.S. Civilian Noninstitutionalized Population.

## Suggested Citation

Cohen, S. Differentials in the Concentration of Health Expenditures across Population Subgroups in the U.S., 2012. Statistical Brief #448. September 2014. Agency for Healthcare Research and Quality, Rockville, MD. http://meps.ahrq.gov/mepsweb/data_files/publications/st448/stat448.pdf

AHRQ welcomes questions and comments from readers of this publication who are interested in obtaining more information about access, cost, use, financing, and quality of health care in the United States. We also invite you to tell us how you are using this Statistical Brief and other MEPS data and tools and to share suggestions on how MEPS products might be enhanced to further meet your needs. Please email us at MEPSProjectDirector@ahrq.hhs.gov or send a letter to the address below:

Steven B. Cohen, PhD, Director
Center for Financing, Access, and Cost Trends
Agency for Healthcare Research and Quality
540 Gaither Road
Rockville, MD 20850

Figure 1 Distribution of health expenditures for the U.S. population by magnitude of expenditure and mean expenditures, 2012

U.S. Population | Health expenditures | Mean expenditures
Top 1% | 22.7% | $97,956
Top 5% | 50.0% | $43,058
Top 15% | 66.0% | $28,468
Top 25% | 86.7% | $14,944
Top 50% | 97.3% | $8,384

Note: Total health expenditures = $1.35 trillion

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2012

Figure 2 Distribution of health care expenditures and mean expenditures for the U.S. population by age, 2012

| | Percent Distribution | Annual Mean
Age 0-17 | Top 5% | 53.8% | $19,520
Age 0-17 | Top 10% | 67.8% | $12,286
Age 0-17 | Top 25% | 85.9% | $6,232
Age 0-17 | Top 50% | 96.1% | $3,484
Age 18-44 | Top 5% | 52.1% | $27,754
Age 18-44 | Top 10% | 68.8% | $18,253
Age 18-44 | Top 25% | 88.7% | $9,410
Age 18-44 | Top 50% | 98.0% | $5,206
Age 45-64 | Top 5% | 47.1% | $57,030
Age 45-64 | Top 10% | 63.1% | $38,199
Age 45-64 | Top 25% | 84.1% | $20,348
Age 45-64 | Top 50% | 96.1% | $11,619
Age 65+ | Top 5% | 34.2% | $63,798
Age 65+ | Top 10% | 49.8% | $46,431
Age 65+ | Top 25% | 74.1% | $27,682
Age 65+ | Top 50% | 91.2% | $17,061

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2012

Figure 3 Distribution of health care expenditures and mean expenditures for the U.S. population by race/ethnicity, 2012

| | Percent Distribution | Annual Mean
White, non-Hispanic | Top 5% | 45.8% | $46,001
White, non-Hispanic | Top 10% | 62.1% | $31,068
White, non-Hispanic | Top 25% | 83.9% | $14,645
White, non-Hispanic | Top 50% | 96.2% | $9,628
Black, non-Hispanic | Top 5% | 55.2% | $38,998
Black, non-Hispanic | Top 10% | 71.9% | $25,242
Black, non-Hispanic | Top 25% | 90.3% | $12,668
Black, non-Hispanic | Top 50% | 98.3% | $6,898
Asian, non-Hispanic | Top 5% | 61.4% | $35,681
Asian, non-Hispanic | Top 10% | 73.5% | $21,291
Asian, non-Hispanic | Top 25% | 90.2% | $10,465
Asian, non-Hispanic | Top 50% | 98.3% | $5,700
Hispanic | Top 5% | 62.4% | $32,753
Hispanic | Top 10% | 76.3% | $20,066
Hispanic | Top 25% | 92.4% | $9,694
Hispanic | Top 50% | 98.8% | $5,182

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2012

Figure 4 Distribution of health care expenditures and mean expenditures for the U.S. population by sex, 2012

| | Percent Distribution | Annual Mean
Male | Top 5% | 56.0% | $44,851
Male | Top 10% | 71.3% | $28,532
Male | Top 25% | 89.6% | $14,327
Male | Top 50% | 98.1% | $7,849
Female | Top 5% | 44.8% | $41,309
Female | Top 10% | 61.1% | $28,178
Female | Top 25% | 83.8% | $15,425
Female | Top 50% | 96.2% | $8,864

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2012

Figure 5 Distribution of health care expenditures and mean expenditures for the U.S. population under age 65 by insurance coverage status, 2012

| | Percent Distribution | Annual Mean
Uninsured | Top 5% | 58.9% | $14,565
Uninsured | Top 10% | 76.9% | $9,432
Uninsured | Top 25% | 94.6% | $4,641
Uninsured | Top 50% | 99.8% | $2,449
Public Insurance | Top 5% | 55.9% | $42,355
Public Insurance | Top 10% | 71.6% | $27,060
Public Insurance | Top 25% | 90.8% | $13,695
Public Insurance | Top 50% | 98.2% | $7,407
Private Insurance | Top 5% | 51.1% | $39,542
Private Insurance | Top 10% | 66.3% | $25,680
Private Insurance | Top 25% | 85.6% | $13,265
Private Insurance | Top 50% | 96.4% | $7,463

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2012

Figure 6 Distribution of health care expenditures and mean expenditures for the U.S. population by number of chronic conditions, 2012

| | Percent Distribution | Annual Mean
No chronic conditions | Top 5% | 57.0% | $13,132
No chronic conditions | Top 10% | 72.0% | $8,304
No chronic conditions | Top 25% | 89.2% | $4,115
No chronic conditions | Top 50% | 98.2% | $2,264
1 chronic condition | Top 5% | 48.8% | $31,460
1 chronic condition | Top 10% | 62.9% | $20,284
1 chronic condition | Top 25% | 82.5% | $10,642
1 chronic condition | Top 50% | 94.7% | $6,103
2 chronic conditions | Top 5% | 46.9% | $53,384
2 chronic conditions | Top 10% | 60.7% | $34,450
2 chronic conditions | Top 25% | 80.1% | $18,165
2 chronic conditions | Top 50% | 92.9% | $10,531
3 chronic conditions | Top 5% | 40.5% | $60,976
3 chronic conditions | Top 10% | 54.9% | $40,919
3 chronic conditions | Top 25% | 76.2% | $22,692
3 chronic conditions | Top 50% | 91.1% | $13,548
4+ chronic conditions | Top 5% | 29.7% | $78,198
4+ chronic conditions | Top 10% | 44.1% | $57,782
4+ chronic conditions | Top 25% | 68.7% | $36,017
4+ chronic conditions | Top 50% | 87.7% | $22,961

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2012

Figure 7 Distribution of health care expenditures and mean expenditures for the U.S. population by income, 2012

| | Percent Distribution | Annual Mean
Poor | Top 5% | 54.3% | $39,887
Poor | Top 10% | 70.3% | $25,933
Poor | Top 25% | 90.6% | $13,298
Poor | Top 50% | 98.5% | $7,233
Near poor | Top 5% | 55.3% | $58,997
Near poor | Top 10% | 71.2% | $38,017
Near poor | Top 25% | 90.3% | $19,233
Near poor | Top 50% | 98.6% | $10,505
Low income | Top 5% | 53.7% | $44,893
Low income | Top 10% | 69.8% | $29,060
Low income | Top 25% | 89.9% | $14,958
Low income | Top 50% | 98.3% | $8,179
Middle incomde | Top 5% | 50.8% | $41,338
Middle incomde | Top 10% | 67.2% | $27,273
Middle incomde | Top 25% | 87.3% | $14,155
Middle incomde | Top 50% | 97.3% | $7,891
High income | Top 5% | 45.4% | $42,815
High income | Top 10% | 61.3% | $28,865
High income | Top 25% | 82.8% | $15,590
High income | Top 50% | 95.6% | $9,003

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2012