# STATISTICAL BRIEF #409 Heart Disease among Elderly Americans: Estimates for the U.S. Civilian Noninstitutionalized Population, 2010

## Highlights

- In 2010, 37.2 percent of the 41.4 million elderly persons in the U.S. reported that they had been diagnosed with heart disease.
- Among elderly persons, non-Hispanic whites, men, and those aged 75 and older were more likely than others to report a diagnosis of heart disease (39.1 percent, 42.4 percent, and 44.3 percent respectively).
- Elderly persons who felt calm and peaceful "all of the time" were less likely than others to have heart disease (27.7 percent).
- There were substantial differences in the diagnosis of heart disease for those with and without hypertension (45.0 percent versus 25.8 percent), high cholesterol (45.5 percent versus 24.8 percent), diabetes (50.6 percent versus 34.1 percent), and limitations in physical functioning (52.1 percent versus 30.6 percent).
- Persons with heart disease were more than twice as likely to have an inpatient hospital stay (27.4 percent versus 11.3 percent) and had average annual health expenditures that were a little more than double the average for individuals without a diagnosis of heart disease ($14,504 versus $7,108).

## Introduction

Heart disease, which includes coronary heart disease, angina, and heart attacks, is the leading cause of death in the U.S., accounting for almost 1 in every 4 deaths. Among the elderly (age 65 and older) there were nearly 500,000 deaths due to heart disease in 2010, or 26.5 percent of all deaths for this age group.^1^ Heart disease is the leading cause of death for both men and women and for most racial/ethnic groups including whites, blacks, and Hispanics. A number of factors including high blood pressure, high LDL cholesterol, diabetes, being overweight or obese, and physical inactivity all increase the risk of heart disease.^2^ The elderly are particularly vulnerable as heart disease-related morbidity and mortality both increase with age.^3^ More than 1 in 3 elderly adults in the U.S. civilian noninstitutionalized population was diagnosed with heart disease in 2010.^4^

This Statistical Brief presents data from the 2010 Medical Expenditure Panel Survey (MEPS) on the percentage of elderly persons in the U.S. population who have ever been told by a doctor, or other health professional, that they have heart disease. This Brief examines variation in the percentage of elderly persons diagnosed with heart disease by demographic and socioeconomic characteristics and selected risk factors. The Brief also compares health care use and expenditures for elderly persons with, and without, a diagnosis of heart disease.

Only differences that are statistically significant at the 0.05 level are discussed in the text.

## Findings

In 2010, 37.2 percent of the 41.4 million elderly (age 65 and older) persons in the U.S. civilian noninstitutionalized population had been diagnosed at some time by a doctor as having coronary heart disease, angina, myocardial infarction (heart attack), or other unspecified heart disease. The following sections describe variations in the percentage of elderly persons with heart disease by selected characteristics.

### Demographic and socioeconomic characteristics (figures 1-3)

In 2010, there were significant differences by sex, age, race/ethnicity, and geographic region in the proportion of elderly persons who had been diagnosed with heart disease (Figure 1 and Figure 2). Among the elderly, heart disease increased with age as those ages 65-69 were the least likely, and those ages 70-74 were less likely than those ages 75 and older to have been diagnosed with the condition (27.3 percent, 35.8 percent, and 44.3 percent respectively). Men were more likely than women to have been diagnosed with heart disease among all elderly individuals (42.4 versus 33.2 percent), among those ages 70-74 (45.0 percent versus 28.2 percent) and among those ages 75 and older (50.4 percent versus 40.0 percent). Non-Hispanic whites were more likely than any of the other racial/ethnic groups-non-Hispanic blacks, Hispanics and non-Hispanic individuals with other/multiple races-to have been diagnosed with heart disease (39.1 percent, 34.0 percent, 24.4 percent, and 30.6 percent respectively). Individuals living in the West were less likely than those living in the Midwest to have been diagnosed with heart disease (34.2 percent versus 39.4 percent).

There were also significant differences in the percentage of elderly persons with heart disease by education and income (Figure 3). Individuals with less than a high school education were more likely than those with at least a college education to have been diagnosed with heart disease (40.9 percent versus 34.0 percent), while persons with high incomes were less likely than middle income and low income individuals to have been diagnosed with heart disease (33.4 percent, 39.7 percent, and 41.1 percent respectively).

### Risk factors (figures 4 and 5)

As shown in Figure 4, the percentage of persons diagnosed with heart disease tends to increase with the level of stress. Elderly individuals who indicated that they felt calm "all of the time" in the previous 4 weeks were the least likely to have been diagnosed with heart disease. Further, those who felt calm "all of the time" or "most of the time" were both less likely to have been diagnosed with heart disease than those who only felt calm "some of the time or little" or "none of the time" (27.7 percent, 36.9 percent, 44.6 percent, and 47.0 percent respectively).

A number of related medical conditions were also associated with an increased rate of heart disease (Figure 5). Persons who had been diagnosed with hypertension were significantly more likely to have heart disease than persons who did not have a diagnosis of hypertension (45.0 percent versus 25.8 percent). Similar differences in the diagnosis of heart disease existed for those with and without high cholesterol (45.5 percent versus 24.8 percent), diabetes (50.6 percent versus 34.1 percent), and limitations in physical functioning (52.1 percent versus 30.6 percent).

### Health care use and expenditures (Figures 6 and 7)

In 2010, elderly persons with a diagnosis of heart disease made more intensive use of health care, on average, than persons without the condition. In particular, elderly individuals with heart disease were more likely than those without the condition to have 5 or more office-based medical visits during the year (71.1 percent versus 52.8 percent). Persons with heart disease were also more than twice as likely to have had at least one inpatient hospital stay (27.4 percent versus 11.3 percent) and to have had at least one emergency room visit (26.3 percent versus 13.0 percent). As a result of their more intensive use of medical care, average annual health expenditures for individuals with heart disease were a little more than double the average expenditure for individuals without a diagnosis of heart disease ($14,504 versus $7,108).

## Data Source

The estimates shown in this Statistical Brief are drawn from the MEPS public use file, MEPS HC-138: 2010 Full Year Consolidated Data File.

## Definitions

### Age

Defined using the last available age for each sampled person.

### Race/ethnicity

Classification by race and ethnicity is mutually exclusive and based on information reported for each family member. Respondents were asked if each family member's race was best described as white, black, Asian, American Indian, Alaska Native, native Hawaiian, Pacific Islander, or multiple races. All persons whose main national origin or ancestry was reported as Hispanic, regardless of racial background, are classified as Hispanic. All non-Hispanic persons whose race was reported as Asian, American Indian, Alaska native, native Hawaiian, or multiple races are classified in the "other" race category. For this analysis, the following classification by race and ethnicity was used: Hispanic (of any race), non-Hispanic black, non-Hispanic white and non-Hispanic other/multiple races.

### Census region

Each MEPS sampled person was classified as living in one of the following four regions as defined by the U.S. Census Bureau:

- Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
- Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, South Dakota, North Dakota, Nebraska, and Kansas
- South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
- West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

### Education

Education is measured as the highest level of education each individual has attained. We use the following three education categories:

- Less than high school: No HS diploma, GED or equivalent.
- High school graduate: HS diploma, GED or equivalent, or other degree.
- College graduate: Bachelor's, Master's, or Doctorate.

### Income

Each person in the survey sample was classified according to the total yearly income of his or her family. Within a household, all individuals related by blood, marriage, or adoption were considered to be a family. Personal income from all family members was summed to create family income. Poverty status is the ratio of family income to the federal poverty thresholds, which control for family size and age of the head of family. Categories are defined as follows:

- Poor/near poor income: People in families with income of 125 percent of the Federal poverty line or less, including those who reported negative income.
- Low income: People in families with income from over 125 percent through 200 percent of the Federal poverty line.
- Middle income: People in families with income from over 200 percent through 400 percent of the Federal poverty line.
- High income: People in families with income over 400 percent of the Federal poverty line.

### Stress

The following question from the Self-Administered Questionnaire was used as a measure for stress: "How much of the time during the past 4 weeks have you felt calm and peaceful? All of the time, most of the time, some of the time, a little of the time, or none of the time?"

### Heart disease

Persons who were ever told by a doctor or other health professional that they had coronary heart disease, angina, heart attack (or myocardial infarction), or other unspecified heart disease were classified as having heart disease.

### Diabetes

Persons who were ever told by a doctor or other health professional that they had diabetes or sugar diabetes were classified as having diabetes.

### High cholesterol

Persons who were ever told by a doctor or other health professional that they had high cholesterol were classified as having high cholesterol.

### Hypertension

Persons who were told by a doctor or other health professional, on two or more different visits, that they had hypertension, or high blood pressure, were classified as having hypertension.

### Functional Limitation

Persons who had difficulties walking, climbing stairs, grasping objects, reaching overhead, lifting, bending or stooping, or standing for long periods of time were classified as having a functional limitation.

## About MEPS-HC

The Medical Expenditure Panel Survey (MEPS) collects nationally representative data on health care use, expenditures, sources of payment, and insurance coverage for the U.S. civilian noninstitutionalized population. MEPS is cosponsored by the Agency for Healthcare Research and Quality (AHRQ) and the National Center for Health Statistics (NCHS). More information about MEPS can be found on the MEPS Web site at http://www.meps.ahrq.gov/.

## References

For a detailed description of the MEPS-HC survey design, sample design, and methods used to minimize sources of nonsampling error, see the following publications:

Cohen J. (1997). Design and Methods of the Medical Expenditure Panel Survey Household Component.
Cohen S. (1997). Sample Design of the 1996 Medical Expenditure Panel Survey Household Component.
Cohen, S. Design Strategies and Innovations in the Medical Expenditure Panel Survey. Medical Care, July 2003: 41(7) Supplement: III-5-III-12. 12865722
Ezzati-Rice T.M., Rohde F., Greenblatt J. (2008). Sample Design of the Medical Expenditure Panel Survey Household Component, 1998-2007.

## Suggested Citation

Carroll, W. and Miller, G. E. Heart Disease among Elderly Americans: Estimates for the U.S. Civilian Noninstitutionalized Population, 2010. Statistical Brief #409. June 2013. Agency for Healthcare Research and Quality, Rockville, MD. http://www.meps.ahrq.gov/mepsweb/data_files/publications/st409/stat409.pdf

AHRQ welcomes questions and comments from readers of this publication who are interested in obtaining more information about access, cost, use, financing, and quality of health care in the United States. We also invite you to tell us how you are using this Statistical Brief and other MEPS data and tools and to share suggestions on how MEPS products might be enhanced to further meet your needs. Please email us at MEPSProjectDirector@ahrq.hhs.gov or send a letter to the address below:

Steven B. Cohen, PhD, Director
Center for Financing, Access, and Cost Trends
Agency for Healthcare Research and Quality
540 Gaither Road
Rockville, MD 20850

1 Centers for Disease Control and Prevention, National Center for Health Statistics. Multiple Cause of Death 1999-2010 on CDC WONDER Online Database released 2012. Data are from the Multiple Cause of Death Files, 1999-2010.

2 Centers for Disease Control and Prevention. Division for Heart Disease and Stroke Prevention. Heart Disease Fact Sheet. Accessed on February 13, 2013. http://www.cdc.gov/dhdsp/data_statistics/fact_sheets/fs_heart_disease.htm.

3 National Center for Health Statistics (U.S.). Health, United States, 2011: With Special Feature on Socioeconomic Status and Health. Hyattsville, MD. 2012 May.

4 Authors' calculations from the 2010 Medical Expenditure Panel Survey Household Component.

Figure 1 Percentage with reported heart disease by sex and age: Adults age 65 and older, 2010

| Sex | | Age | | | Male vs Female by Age
Total | Male | Female | 65-69 | 70-74 | 75+ | 65-69 | 70-74 | 75+ | 65-69 | 70-74 | 75+
37.2% | 42.4% | 33.2% | 27.3% | 35.8% | 44.3% | 29.2% | 25.6% | 45.0% | 28.2% | 50.4% | 40.0%

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2000 and 2010

Figure 2 Percentage with reported heart disease, by race/ethnicity and region: Adults age 65 and older, 2010

Race/ethnicity | | | | Region
Non-Hispanic white, single race | Non-Hispanic black, single race | Hispanic, any race | Non-Hispanic other/multiple races | Northeast | Midwest | South | West
39.1% | 34.0% | 24.4% | 30.6% | 37.4% | 39.4% | 38.1% | 34.2%

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2000 and 2010

Figure 3 Percentage with reported heart disease by educational attainment and income: Adults age 65 and older, 2010

Education | | | Income
Less than HS | HS/GED/Other | College Grad | Poor/near poor | Low income | Middle income | High income
40.9% | 37.4% | 34.0% | 36.9% | 41.1% | 39.7% | 33.4%

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2000 and 2010

Figure 4 Percentage with reported heart disease by stress level: Adults age 65 and older, 2010

During the past 4 weeks, felt calm and peaceful
All of the time | Most of the time | Some of the time | Little or none of the time
27.7% | 36.9% | 44.6% | 47.0%

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2000 and 2010

Figure 5 Percentage with reported heart disease by selected comorbidities and risk factors: Adults age 65 and older, 2010

Hypertension | | High cholesterol | | Diabetes | | Limitation in physical functioning
With condition | Without condition | With condition | Without condition | With condition | Without condition | With condition | Without condition
45.0% | 25.8% | 45.5% | 24.8% | 50.6% | 34.1% | 52.1% | 30.6%

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2000 and 2010

Figure 6 Health care utilization by presence of heart disease: Adults age 65 and older, 2010

Office visits - 5 or more | | At least 1 inpatient stay | | At least 1 ER stay
With heart disease | Without heart disease | With heart disease | Without heart disease | With heart disease | Without heart disease
71.1% | 52.8% | 27.4% | 11.3% | 26.3% | 13.0%

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2000 and 2010

Figure 7 Mean total health care expenditure by presence of heart disease: Adults age 65 and older, 2010

All persons | Without heart disease | With heart disease
$9,858 | $7,108 | $14,504

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2000 and 2010