# STATISTICAL BRIEF #401 Expenses for Hospital Inpatient Stays, 2010

## Highlights

- In 2010, expenses for hospital inpatient stays accounted for nearly one-third of all health care expenses for the U.S. civilian noninstitutionalized population. These expenses were paid primarily by private insurance plans and Medicare.
- The average expenditure for a hospital stay in 2010 was $13,131 while the median per stay expenditure was $7,587.
- While total expenses for a hospital stay increased with length of stay, the average per diem decreased as the length of stay increased.
- On average, hospital stays involving surgery were about twice as expensive as other stays.

## Introduction

Though only a relatively small proportion of the population has an inpatient stay in a given year, expenditures for hospitalization account for nearly one-third of all medical expenses. This Statistical Brief presents data from the Household Component of the Medical Expenditure Panel Survey (MEPS-HC) on payments for hospital inpatient stays among persons in the U.S. civilian noninstitutionalized population in 2010. Descriptive data on aggregate expenses, payment sources, variations by age and gender, as well as information on expenses per stay and per diem, are presented. All differences between estimates discussed in the text are statistically significant at the 0.05 level or better.

## Findings

### Sources of payment

In 2010, hospital inpatient stays accounted for 31.0 percent of total health care expenses for the U.S. civilian noninstitutionalized population (Figure 1). Private insurance (40.9 percent) and Medicare (34.7 percent) paid for the overwhelming majority of hospital inpatient expenses. Out-of-pocket payments by individuals and families comprised only 2.5 percent of payments for hospital inpatient care.

### Variations in likelihood of expenses

Overall, 7.1 percent of the civilian noninstitutionalized population had expenses for an inpatient hospital stay in 2010 (Figure 2). The percentage of persons that had expenses for inpatient hospital stay(s) increased substantially with age overall and for both males and females. Only 2.5 percent of children under age 18 had expenses for an inpatient hospital stay compared to 17.4 percent of persons age 65 and over. Females ages 18–44 were substantially more likely to have inpatient expenses than their male counterparts (9.3 versus 2.6 percent). A large portion of this differential is attributable to hospitalizations for childbirth.

### Expenses per stay

In 2010, the average total payment from all sources (private insurance, Medicare, Medicaid, out-of-pocket payments, and other miscellaneous sources) for a hospital inpatient stay was $13,131 (Figure 3). However, there was substantial variation across stays in hospital inpatient expenses. For example, expenses for about 10 percent of stays were less than $1,308 (10th percentile) while, at the other extreme, expenses for the top 10 percent of stays were greater than $30,883 (90th percentile). The highest expenditure visits had a disproportionate impact on the average. Consequently, the median expense for a hospital stay of $7,587 was substantially lower than the mean expense ($13,131).

### Per diem expenses

Overall, the average expense per night for a hospitalization in 2010 was $4,221 while the median per diem was about $2,362 (Figure 4). While total expenses for a hospital stay increased with length of stay, the average per diem decreased as the length of stay increased. For example, the average per diem expense was $7,985 for one night stays (about 24 percent of stays) versus $2,176 for stays of five nights or longer (about 31 percent of stays). Similarly, the median per diem expense decreased from $4,651 for one night stays to $1,513 for stays of five nights or longer.

### Stays involving surgery

Hospital stays during which a surgical procedure was performed (about one-third of inpatient discharges in 2010) tended to be more expensive than other hospitalizations (Figure 5). In 2010, the average total expense per stay was $19,440 for those involving surgery—about twice as high as the average for other hospital stays ($10,000). Similarly, the average expense per diem was about three times as large for stays involving surgery ($7,566) than those without surgery ($2,560).

## Data Source

The estimates in this Statistical Brief are based upon data from the MEPS 2010 Full Year Consolidated File (HC-138) and Hospital Inpatient Stays File (HC-135D).

## Definitions

### Expenses (also referred to as expenditures or payments)

Payments from all sources for hospital inpatient stays reported by respondents in the MEPS-HC. Sources include direct payments from individuals, private insurance, Medicare, Medicaid, Workers' Compensation, and miscellaneous other sources. Expenditures include those for both facility and separately billed physicians' services and expenses for emergency room services that immediately preceded a hospital stay are typically included. A negligible proportion of inpatient stays had no expenses associated with the stay (i.e., no payments made).

### Per diem

Per diem expenses were computed for each stay by dividing the total expenses for the stay by the number of nights in the hospital. The number of nights was considered to be one for the small proportion of stays with identical admission and discharge dates reported (i.e., zero night stays).

## About MEPS-HC

MEPS-HC is a nationally representative longitudinal survey that collects detailed information on health care utilization and expenditures, health insurance, and health status, as well as a wide variety of social, demographic, and economic characteristics for the U.S. civilian noninstitutionalized population. It is cosponsored by the Agency for Healthcare Research and Quality and the National Center for Health Statistics.

For more information about MEPS, call the MEPS information coordinator at AHRQ (301-427-1406) or visit the MEPS Web site at https://www.meps.ahrq.gov/.

## References

For a detailed description of the MEPS-HC survey design, sample design, and methods used to minimize sources of nonsampling error, see the following publications:

Cohen J. (1997). Design and Methods of the Medical Expenditure Panel Survey Household Component.
Cohen S. (1997). Sample Design of the 1996 Medical Expenditure Panel Survey Household Component.
Cohen, S. Design Strategies and Innovations in the Medical Expenditure Panel Survey. Medical Care, July 2003: 41(7) Supplement: III-5-III-12. 12865722
Ezzati-Rice T.M., Rohde F., Greenblatt J. (2008). Sample Design of the Medical Expenditure Panel Survey Household Component, 1998-2007.

## Suggested Citation

Mirel, L.B. and Carper, K. Expenses for Hospital Inpatient Stays, 2010. Statistical Brief #401. February 2013. Agency for Healthcare Research and Quality, Rockville, MD. http://www.meps.ahrq.gov/mepsweb/data_files/publications/st401/stat401.pdf

AHRQ welcomes questions and comments from readers of this publication who are interested in obtaining more information about access, cost, use, financing, and quality of health care in the United States. We also invite you to tell us how you are using this Statistical Brief and other MEPS data and tools and to share suggestions on how MEPS products might be enhanced to further meet your needs. Please email us at MEPSProjectDirector@ahrq.hhs.gov or send a letter to the address below:

Steven B. Cohen, PhD, Director
Center for Financing, Access, and Cost Trends
Agency for Healthcare Research and Quality
540 Gaither Road
Rockville, MD 20850

Figure 1 Payments for hospital inpatient stays, 2010

Inpatient expenses | Payments
All expenses ($1,263 billion)
Prescribed medicines | 21.4%
Hospital inpatient | 31.0%
Ambulatory care | 36.1%
Other | 11.4%
Inpatient sources of payment
Private insurance | 40.9%
Medicare | 34.7%
Medicaid | 12.4%
Out-of-pocket | 2.5%
Other | 9.4%

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2010

Figure 2 Percentage of persons with inpatient expenses, by age and gender, 2010

Overall | | | | | Male | | | | Female
Overall | <18 | 18-44 | 45-64 | 65+ | <18 | 18-44 | 45-64 | 65+ | <18 | 18-44 | 45-64 | 65+
7.1% | 2.5% | 6.0% | 7.9% | 17.4% | 2.2% | 2.6% | 7.0% | 17.7% | 2.7% | 9.3% | 8.7% | 17.2%

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2010

Figure 3 Distribution of inpatient expenses per stay, 2010

| Average | 10th percentile | 25th percentile | 50th percentile (median) | 75th percentile | 90th percentile
Dollars | 13,131 | 1,308 | 4,046 | 7,587 | 14,614 | 30,883

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2010

Figure 4 Inpatient expenses per diem, by length of stay, 2010

| Overall | 1 night | 2 nights | 3 nights | 4 nights | 5+ nights
Mean | $4,221 | $7,985 | $4,023 | $3,802 | $2,662 | $2,176
Median | $2,362 | $4,651 | $3,058 | $2,546 | $1,948 | $1,513

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2010

Figure 5 Average inpatient expenses for stays with and without surgery, 2010

| Per stay | Per diem
Surgery | $19,440 | $7,566
No surgery | $10,000 | $2,560

Source: Center for Financing, Access, and Cost Trends, AHRQ, Household Component of the Medical Expenditure Panel Survey, 2010