# Breakout Group Sessions

Each participant in the Surgeon General’s Women’s Mental Health Workshop was assigned to one of eight workgroups. The basis for these assignments was not associated with individual specialties or areas of interest; rather, it was designed to ensure diversity and even numbers across each of the workgroup topic areas. These topic areas reflected the eight “cluster areas” identified through the series of background activities leading up to the workshop. As described above, these activities included a concept mapping exercise, key-informant interviews, facilitated discussions, and a targeted literature review. The breakdown of the eight workgroups was as follows:

Group 1: Biological and developmental factors

Group 2: Specific mental disorders

Group 3: Trauma, violence, and abuse

Group 4: Social stress factors and stigma

Group 5: Identification and intervention issues

Group 6: Treatment, access, and insurance

Group 7: Health systems issues

Group 8: Protective and resilience factors

The workgroups were given the task of addressing three major objectives. These included:

- Objective 1: Review and prioritize the significant issues affecting the mental health of women and girls within the identified cluster area.
- Objective 2: Develop practical recommendations for the production of communiqués and toolkits related to the issues of that cluster area.
- Objective 3: Prepare a series of PowerPoint slides highlighting three key priority issues from the cluster area. In addition, for each key priority issue identify the major messages, suggested format, target audience, dissemination strategy, funding sources, and any overarching cultural concerns to be taken into consideration.

Each workgroup was composed of 12–14 participants and facilitated by two individuals, including one Federal representative and one expert from the field. The facilitators conducted introductions, reviewed the workgroup objectives, and conducted a prioritization exercise to determine the highest priority issues within their cluster area. A list of potential communiqués and toolkits, based on recommendations from the background leadership interviews and facilitated discussions, was distributed to the workgroup members to spur ideas and discussions. This list is included in Appendix B.

## Workgroup 1: Biological and Development Factors

Workgroup 1: Biological and Developmental Factors At-A-Glance

Priorities

1. Understanding the biobehavioral bases for sex and gender differences as related to mental health
2. Taking a life span approach to mental health – understanding sex and gender differences in etiology, course, and high-risk periods
3. Understanding male and female differences in biobehavioral response to psychotherapeutic and behavioral mental health treatment (including side effects, efficacy, and compliance)

Messages

- Biobehavioral factors underlie sex and gender differences in the way people think and feel.
- Biobehavioral differences between men and women are known through a small but growing body of research.
- Greater knowledge will enhance our capacity to understand the etiology, prevention and treatment of mental health disorders and inform gender-based prevention and treatment strategies.
- Early puberty is a high-risk period for specific mental disorders (for adolescent audiences).
- Research shows that important events and times in a woman’s or girl’s life increase the likelihood of developing a mental disorder. Gender-specific prevention and treatments targeted to specific events across the life span are more effective.
- Interventions may have different effects on men and women with selected mental health conditions. Women should be aware that a variety of treatments are available and should be encouraged to pursue the ones that best meet their needs.

Products

Fact sheets on sex and gender differences, lists of organizations, summary of scholarly articles, Web sites, TV messages, age-specific videos, and pamphlets

The Biological and Developmental Factors Breakout Group was given the list of issues to prioritize indicated in the following box.

Issues to Prioritize

1. Understanding basic neurological sex differences
2. The need for increased effort to relate biological and genetic mental health research to sex and gender differences in the prevalence and course of mental disorders
3. Sex and gender differences in treatment response (both efficacy and side effects)
4. Factors contributing to the emergence of sex and gender differences in mental disorders in adolescents
5. Sex and gender differences and the effects of psychotherapeutic medications
6. The neurobiology and psychology of sex and gender differences in social behavior and attachment
7. Understanding the biological bases of normative sex and gender differences
8. How the developmental phases of young females affect their mental health status as women

### Defining sex and gender

The group began with a discussion of the distinctions between sex and gender, leading to the following definitions: Sex is a biological construct defined by the organs with which a person is born. It changes little over time or across different cultures. In contrast, gender is a societal construct that reflects a person’s sex as it figures in a context of culture, family, and social environment.

It was noted that these definitions are further complicated by the need to incorporate lesbian, gay, bisexual, and transgender (LGBT) concerns.

### The role of biology versus environment

A major point of discussion for the group was the role of biology and the question of whether biology should be viewed separately or within a social context. The point was made that biological factors often unfold in a way that is influenced by the environment. However, as one researcher noted, some mental illnesses are responsive to medical treatment, so that the role of biology cannot be ruled out – especially since much information has been gained through studies and clinical trials on the role of biology. This raises the issue, which constitutes an ongoing debate between scientists and advocates, regarding who should be the source of expertise.

### Taking a life span approach

It was noted that while the morning workshop presentations had focused on adults there also is a need to understand and transmit the message that women and girls are not the same. The importance of looking across the continuum of women’s lives and taking a life span approach to mental health issues was highlighted. Workgroup members also commented on the importance of acknowledging that there are critical high-risk periods during a woman’s life when mental disorders are more likely to occur. This concept of a life span approach was threaded throughout the workgroup’s discussions and ultimately was identified as a priority issue.

Following this discussion, the group was able to synthesize and redefine three priorities from the eight under consideration. Their resulting key priorities are listed below.

Key Priorities: Workgroup 1 Biological and Developmental Factors

1. Understanding the biobehavioral bases for sex and gender differences as related to mental health
2. Taking a life span approach to mental health – understanding sex and gender differences in etiology, course, and high-risk periods
3. Understanding male and female differences in biobehavioral response to psychotherapeutic and behavioral mental health treatment (including side effects, efficacy, and compliance)

#### Key Priority #1: Understanding the biobehavioral bases of sex and gender differences as related to mental health

##### Discussion

It was suggested that there is a dearth of research regarding sex and gender differences in the brain and that the brain must be understood before addressing environmental factors. The group discussed the need for a clear understanding of cognitive processes, emotions, and interpersonal functioning.

##### Audiences

Participants discussed the need to address several different audiences, including the medical research community, the general public, and policymakers. One suggestion was that messages targeting policymakers also could be put into language for the general public. There also was discussion about targeting specific audiences within the general population, such as families, teachers, and researchers. In the end, the group agreed to target two primary groups comprised of:

- The general public
- A combination of policymakers, research funders, providers, and trainers

“Clinical experience is an essential part of evidence-based practices. What is lacking now is an understanding of the full scope of the existing evidence base. There is a tension between clinical and empirical data. The clinical data on biological differences may be stronger than most suspect, even if there is a shortage of empirical data.”

– Breakout group member

##### Messages

The group crafted several messages, adapted to different target audiences. These include the following:

Message to the general public

Biobehavioral factors underlie sex and gender differences in the way people think and feel.

The point was made that the sex and gender differences referred to in the above message would have to be further specified and demonstrated.

Message to policymakers

Biobehavioral differences between men and women are known through a small but growing body of research. Greater knowledge will enhance our capacity to understand the etiology, treatment, and prevention of mental health issues and to inform sex and gender based prevention and treatment efforts.

Message for all audiences

Greater knowledge will enhance our capacity to understand the etiology, prevention, and treatment of mental health disorders and to inform sex and gender based prevention and treatment strategies.

##### Formats

The group’s recommended formats included:

- A report including facts and implications of sex and gender differences that also would include a list of organizations supporting sex and gender specific treatment and awareness
- A pamphlet, which would accompany the report and include empirical data on selected mental health conditions for ethnic minorities and underserved populations

##### Cultural Concerns

Participants noted the importance of having providers, the general public, and trainers understand that mental health symptoms manifest differently for ethnic minorities. Gaps in care for minorities need to be addressed as well, it was argued, though there is concern that the existing data are uneven. One participant shared the information that several fact sheets already exist on the topic and can be obtained through the Society for Women’s Health Research.

#### Key Priority #2: Taking a life span approach to understanding sex and gender differences in the etiology, course, and high-risk periods of mental health conditions

##### Discussion

One participant emphasized the importance of examining the ways in which different periods in a woman’s life affect her mental health; another added that mental health problems carry different economic, social, and personal costs at various points of the life span. The point was also made that there are sex and gender differences in the etiology, course, and high-risk periods of mental health conditions over a life span.

It also was noted that taking a sex and gender based approach to mental health can be beneficial to both men and women, including understanding more about what causes mental health problems at different times in a person’s life.

##### Audiences

The group worked to identify key periods of the life span, which deserve special attention regarding mental health concerns. Members agreed that in tailoring the message across the life span, the following audiences should be targeted:

- Adolescents
- Postpartum mothers
- Parents
- Caregivers
- Researchers
- Policymakers
- Providers

##### Messages

The group crafted several messages, adapted to different target audiences. These include the following:

Message to the adolescent audience

Early puberty is a high-risk period for specific mental disorders.

Message for all audiences

Research shows that important events and times of a woman’s or girl’s life increase the likelihood of developing a mental disorder. Sex and gender specific prevention and treatments targeted to specific events across the life span are more effective.

##### Formats

The group brainstormed about ways to reach the various age-group audiences. One participant emphasized the importance of bringing the message to the audience, rather than expecting the audience to request a Surgeon General publication. Suggested potential venues for reaching different audiences included:

- Web sites
- MTV and informational programming concerning emotional crises
- Public service announcements that could be delivered through community centers and churches, especially targeting adult women
- 1–800 phone numbers

##### Cultural Concerns

Participants noted that any materials produced should be translated into multiple languages. Furthermore, they recommended that the message should consider and incorporate cultural concerns and mores and be disseminated in age and culturally appropriate settings.

#### Key Priority #3: Understanding male and female differences in biobehavioral response to psychotherapeutic and behavioral mental health treatment (including efficacy, side effects, and compliance)

##### Discussion

Participants noted that there are new treatment models that are person centered and others based on a social model of disability. It is important, they commented, for the general public to know that treatment models are transitioning; women have the right to multiple options and should assert themselves when it comes to their own treatment.

Further points that were raised on this topic included the following:

- There are multiple treatment options, and it is important to understand that what works best for women might differ from what works best for men.
- There are limited data suggesting that the response to a given treatment may differ among men and women. More research is needed that is not merely secondary analysis.
- There are choices for treatment that allow consumers to pursue different options if a particular treatment is not working. Having options is empowering to the consumer.
- An important takeaway is that there are a variety of treatments available that may or may not be influenced by sex and gender.

The group worked to identify health issues germane to women that should be considered when receiving mental health treatment. Their list included:

- The menstrual cycle
- Menopause
- Medications
- Pregnancy
- Age-related hormonal fluctuations

##### Audiences

For issues related to sex and gender differences, the group identified the following audiences:

- Educators
- Researchers
- Members of the general public
- Providers – with special emphasis being placed on mental health providers

##### Messages

The group crafted one message for all audiences:

There is evidence that interventions may have different effects on men and women with selected mental health conditions. Women should be aware that a variety of treatments are available and should be encouraged to pursue the ones that best meet their needs.

##### Formats

The workgroup identified the following channels for disseminating the message:

- Following the BodyWise Model (developed by OWH) – producing and adjusting a two-page fact sheet to target specific audiences
- Using the 4-Women Web site (developed and maintained by OWH)
- Listservs
- Information Clearinghouse – developing a high-level, government-supported clearinghouse of information that the public could access.

##### Cross-cutting cultural concerns

In formatting the message, the group discussed how to incorporate culturally sensitive and accurate material. They recognized that cultural attitudes may cause shame and associate stigma with mental illness. There was agreement that the message should include information regarding different ethnicities’ responses to treatment and incorporate and validate the use of alternative healing methods.

Workgroup 1 Participants

Facilitators

Cora Wetherington, Ph.D., National Institute on Drug Abuse

Kimberly Yonkers, M.D., Yale University School of Medicine

Participants

Cheryl Bowers-Stephens, M.D., M.B.A., Louisiana Department of Health and Hospitals

Sylvia Caras, People Who

Nereida Correa, M.D., Albert Einstein College of Medicine

Mary Gee, B.A., Eating Disorders Coalition for Research Policy and Action

Melva Green, M.D., American Psychiatric Association

Phyllis Greenberger, M.S.W., Society for Women’s Health Research

Gail Hutchings, M.P.A., SAMHSA

Nadine Kaslow, Ph.D., Emory University School of Medicine

Ruby Martinez, R.N., National Latino Behavioral Health Association

Caroline Mazure, Ph.D., Yale University School of Medicine

Richard Nakamura, Ph.D., National Institute of Mental Health

Eileen Ouellette, M.D., J.D., FAAP, American Academy of Pediatrics

## Workgroup 2: Specific Mental Disorders

Workgroup 2: Specific Mental Disorders At-A-Glance

Key Priorities

1. Developing communiqués and toolkits focused on children and adolescent girls
2. Developing communiqués and toolkits focused on adult women
3. Developing communiqués and toolkits focused on older women

Messages

- Mental health is essential to health (for children and adolescents).
- Mental health is essential to health. Recovery is the goal (for adult women).
- Mental health is essential to health. Good mental health is possible even in the absence of good physical health (for older women).

Products

Educational kits for parents and educators, toolkits for group facilitation, Web-based tools, iPod messages, visual non-literacy materials, multi-lingual and low literacy print materials, audio materials, videos, story-telling formats, PSAs.

The Specific Mental Disorders Workgroup was given a long list of issues to consider. They were asked to prioritize 3 from the 20 presented in the box below.

Issues to Prioritize

1. Substance use and abuse (alcohol, illicit prescription use, tobacco, other drugs)
2. Loss, depression, and anxiety across the life span
3. Perinatal depression and anxiety and its effects on the family
4. Adolescent depression, anxiety, and suicide
5. The impact of race, ethnicity, culture, class, sexual orientation, and age on the expression of symptoms
6. The relationship between depression, anxiety, and other negative mood states and substance abuse, especially smoking
7. Recognition of enduring effects of depression and anxiety
8. Comorbidity of mental disorders (depression, anxiety, mood disorders, substance abuse, including smoking, eating disorders, harming oneself, suicide)
9. The impact on children of parental institutionalization (psychiatric, correctional, and military deployment)
10. Understanding why women are more prone to suicide attempts than men
11. The interaction of mental disorders with other illnesses, as both cause and consequence (e.g., cardiovascular disease, diabetes)
12. Eating disorders
13. Obesity and body image issues
14. Research on serious mental illness in women
15. Sex and gender differences in course, pathophysiology, and treatment response in mental disorders
16. Posttraumatic stress disorder
17. Bipolar disorder
18. Schizophrenia
19. Personality disorders
20. Dissociative disorders

### Language and stigma

The group began by discussing the consequences, both positive and negative, of diagnosing and assigning a title to an individual’s symptoms. Some voiced concerns that certain diagnoses carried a stigma that might prevent women from seeking treatment – especially in some ethnic communities. The question was raised regarding whether consumers were being pathologized by terms such as “disorders”. There was a push by some participants to be less label-oriented in favor of being more distress-oriented or reframing issues in a more positive way; for example using terms such as “seeking peace”.

“There is a need for alternative tools besides labels and diagnoses to reach targeted audiences who may already be underserved. Otherwise, if all you have is a hammer, everything is going to look like a nail.”

– Breakout group participant

Others were in favor of embracing a diagnosis. One participant suggested the creation of a crosswalk that could expand the understanding to incorporate physical symptoms and subsequently a more holistic view of a given disorder.

Another comment was that more consideration should be given to thinking outside the box. The concern was voiced that consumers would not pick up a pamphlet titled “Mood Disorders” voluntarily – underscoring the need for tools besides labels and diagnoses to reach the targeted audiences that may already be underserved.

Ultimately, it was noted that the two approaches were not incompatible in terms of disseminating the message. Emphasizing the importance of targeting particular audiences, the suggestion was made that educational materials could be tailored for primary care providers; an overall piece could be crafted to address mental health in relation to overall well-being; and a third educational piece could target communities with high prevalence. It was pointed out that there needs to be a balance between the two approaches and emphasis placed on disseminating specific information.

### Prioritizing the issues

After much discussion about cross-cutting issues, audiences, and what types of tools might be most effective coming from the Surgeon General, this workgroup ultimately identified three major areas of concern:

1. Mood and anxiety disorders, including cross-cutting themes such as culture, faith, family, resiliency, and available treatment options
2. Trauma, including such cross-cutting themes as culture, recovery, and resilience
3. Co-occurrence of mental disorders with medical issues

### Overall audiences and messages

The workgroup identified several cross-cutting themes:

- Culture is an essential consideration.
- Promotion of resilience is an important goal.
- Critical life events can challenge coping.
- Mental health is essential to overall health.

Although the workgroup identified three major age groups as their primary focus for the development of communiqués and toolkits, they also noted the need to address multiple audiences with messages regarding each of these age groups. Those audiences included not only consumers and members of the public but also providers and policymakers.

There was considerable discussion about the types of messages to be conveyed to different audiences – particularly for the general public and underserved audiences. The concern was expressed that messages should be crafted in a language that people use and can understand, and that is culturally appropriate. For example, one person noted that most people do not use many of the terms used in the list of priority issues; they refer more to terms such as “illness”.

Another participant commented that patients do not care about their Beck Depression Inventory score but rather about whether or not they can get up in the morning. This led to the suggestion that messages be reviewed from the bottom up to ask people themselves in venues such as peer-to-peer interviewing questions such as “How do they understand the message?” and “Do we need to develop different tools?”

### Building greater communication between providers and consumers

Another point raised was the need to design tools that could help build bridges between providers and consumers. This was seen as important in helping to move the clinical community to be more responsive and communicative with consumers. It was suggested that this would mean not only incorporating consumer terms into provider materials, but also including clinical terms in materials for consumers. One person added, however, that in order to get providers to pay attention to messages, “you have to come with a hammer” with substantive information and with strategies such as incorporating messages or changes through credentialing bodies or CME credits.

### Translating research and best practices into practice

The issue of how information is translated from research into practice was discussed. The point was made that there is a dearth of hard information on knowledge transfer and that anecdotal evidence would suggest that the translation is not occurring. This led to the suggestion that more information is needed on what it takes for people to become comfortable with a tool, what works, what does not, what should be replicated, what type of training is needed, and where information is distributed.

The hope was shared that the bully pulpit of the Surgeon General would offer a greater opportunity to be heard and discuss mental health in terms of whole health. The suggestion was made that messages with the backing of the Surgeon General then could be distributed through the pipelines and networks of existing organizations – including those represented at this meeting.

### Looking across the life span

As a result of the discussion of specific mental disorders, cross-cutting themes, and target audiences, members of the workgroup began to move toward a developmental and life course approach. Thus, rather than prioritizing specific disorders from the given list, participants felt it was important to give priority to different age ranges and life transitions, emphasizing how those relate to the risks, course, prevention, and treatment of these disorders.

As a result, the group agreed to prioritize their message, audience, and suggested communiqués or toolkits according to three age ranges, including childhood and adolescence, adult women, and older women. These age groups became the framework for the discussion of specific products and the focus of the group’s identified priority areas, as indicated below.

Workgroup 2: Specific Mental Disorders Framework for Developing Toolkits and Communiqués

1. Developing communiqués and toolkits focused on children and adolescent girls
2. Developing communiqués and toolkits focused on adult women
3. Developing communiqués and toolkits focused on older women

The group discussed issues related to particular age groups, such as the importance of focusing on prevention with children and youth. They also looked at issues that cut across different age groups, such as the importance of mental health to overall health. The point was made that this workshop presented an opportunity to get away from the usual silos, defined by funding streams, to make a more integrated, holistic-oriented product.

#### Key Priority #1: Communiqués and toolkits focused on children and adolescents

Several participants viewed the period of childhood and adolescence as an important one for promoting resilience and prevention. They noted that effective toolkits for girls exist – including tools for at-risk girls – that are designed to help build self-esteem and self reliance. It was noted that these types of toolkits would be given more force if the Surgeon General was behind them.

Another topic that generated discussion had to do with girls and young women who are at risk or already living with mental or co-occurring disorders, including those who may not make it always onto the radar screen (e.g., runaways, the growing population of young women in junior college). Several life events and challenges were identified as being particularly associated with this age group, including the effects of trauma, illness, and family breakup or loss. The positive and negative coping mechanisms that girls employ in the face of the challenges were discussed, including behavioral problems, substance abuse, mood symptoms, and resilience.

##### Message

The key message for materials focusing on this age group was:

Mental health is essential to health.

##### Audiences

The identified audiences for this message include:

- Consumers
- Family members
- Health care providers
- Policymakers
- Educators

Dissemination strategies to reach these audiences were mentioned, such as working through schools, teacher associations, and parent-teacher associations.

##### Formats

The suggested formats include:

- For girls
- Information downloadable to an iPod
- Web-based tools
- Toolkits for group facilitation
- For parents
- Educational kits
- For teachers and parole officers
- Toolkits
- For providers
- Continuing education units (CEUs)
- Board exams

##### Cross-cutting cultural concerns

The priority cross-cutting cultural concerns highlighted by this group included:

- The need to improve the pipeline of minority providers
- The need to increase the understanding of cultural and age-specific modes of expression among providers, teachers, and others who interact with children and adolescents

#### Key Priority #2: Communiqués and toolkits focused on adult women

##### Message

The key message for materials focusing on this age group was:

Mental health is essential to overall health. Recovery is the goal.

##### Audiences

A wide audience was identified for this message, including:

Consumers, families, faith-based organizations, providers, policymakers, employers, community organizations, women’s groups, child care providers, criminal justice system, educational institutions, welfare-to-work programs, peer educators and lay home visitors, public housing, vocational rehab programs, AARP, and caregivers

##### Formats

The suggested formats to reach the identified audiences with the identified message include:

- Visual, nonliteracy materials (e.g., film, video, sound)
- Facilitator’s guides (e.g., tool associated with a video) designed with something to deal with emotional reactions that may be triggered through use of this tool
- Self-assessment tools
- Print materials, including multi-language and low-literacy products

##### Cross-cutting cultural concerns

One focus of discussion on this topic was the need to understand points of intervention for particular groups of women. For example, it was noted that self-determination and self-reliance are key within the African-American community and lack of these can be seen as a real failure. Thus, to break down stigma, it is important that mental health tools be adapted to different cultural groups in ways that address how they view mental health and illness.

The group stressed the importance of ensuring that tools are reviewed and developed by members of specific communities and cultures – and that these reflect knowledge of how individuals can be reached within their cultural context. Examples were shared of materials that successfully bridge different cultures, such as the book Woman Who Glows in the Dark, which was written by Elena Avila, a nurse who practiced both Western medicine and indigenous folk healing.

#### Key Priority #3: Communiqués and toolkits focused on older adult women

##### Message

The key message for materials focusing on this age group was:

Mental health is essential to overall health. Good mental health is possible even in the absence of good physical health.

##### Audiences

Numerous audiences were identified for this message and this age group. They included:

AARP; employers; nonclinical retirement communities; faith-based organizations; beauty parlors; bingo parlors; adult day care centers; community services for the elderly; areawide Agency on Aging; nursing centers and assisted living centers; and public health services, such as Medicare, SSI, and Medicaid

##### Formats

The recommendations regarding formats included:

- Large-print materials
- Audio and low-vision materials
- Information that is short and sweet
- Videos
- PSAs (celebrity voices may resonate more with harder to reach populations)
- No acronyms
- Color contrast
- Storytelling and oral histories

##### Cross-cutting cultural concerns

A number of issues were identified as relating particularly to this group. One set of issues had to do with generational differences, respect for elders, caring for other family members, or being cared for by family members, and end-of-life concerns. Others included issues of poverty and restricted income, privacy, indirect communications, and the use of multiple medications.

##### Opportunities for collaboration

This topic generated considerable discussion and development of partnering opportunities. Suggestions regarding potential funders and partners included:

- Private foundations (e.g., Kaiser, the Robert Wood Johnson Foundation, the Commonwealth Fund, Pew, Ford)
- National Foundation for Mental Health
- American Psychological Association
- National Association of Mental Health
- Business partners such as Estee Lauder, Ford, The Body Shop, Avon, Amway, and Tupperware
- Interdisciplinary partners, such as the National Hispanic Medical Association, National Hispanic Nurses Association, and faith-based groups, women’s organizations
- Accreditation organizations
- Women’s athletics organizations
- International groups that have shown an interest in mental health and women (e.g., World Bank, WHO, the United Nations)
- Educational organizations
- Migrant centers
- National Association of Commissioners for Mental Health
- National spokespersons, such as Oprah Winfrey or the head of women’s health for Aetna

Workgroup 2 Participants

Facilitators

Catherine Roca, M.D., National Institute of Mental Health

Ellen Frank, Ph.D., University of Pittsburgh Medical Center

Participants

Andrea Blanch, Ph.D., Center for Women, Violence and Trauma

Silvia Canetto, Ph.D., Colorado State University

Linda Chaudron, M.D., M.S., University of Rochester

Judith Cook, Ph.D., University of Illinois at Chicago

Helen Coons, Ph.D., Women’s Mental Health Association

Charlene Doria-Ortiz, Center for Health Policy Development, Inc.

Linda Frisman, Ph.D., University of Connecticut

Susan Gorin, C.A.E., National Association of School Psychologists

Barbara Hylard, Depression and Bipolar Support Alliance

Frances Murphy, M.D., M.P.H., Veterans Health Administration and President’s Mental Health Initiative

Linda Prescott, Sister Witness International

Barbara Yee, Ph.D., University of Hawaii

## Workgroup 3: Trauma, Violence, and Abuse

Workgroup 3: Trauma, Violence, and Abuse At-A-Glance

Priorities

1. Developmental and mental health effects of trauma
2. Integration of health and mental health
3. Effects of emotional abuse

Messages

- What is trauma and how common is it?
- (Convey the human face of trauma, use everyday language, promote individual and community action to address trauma, violence, and abuse)
- Recovery is possible.
- Mental health is an essential part of physical health.
- There is no separation between mind, body, brain, and behavior.
- There is a need to develop psychological literacy around the mind-body connection.
- Emotional abuse is “soul murder”.
- Emotional abuse includes neglect, which is the “violence of silence”.
- Emotional abuse negates your existence.

Products

Letter from the Surgeon General; PSAs; toolkits; Institute of Medicine report on trauma; fact sheets on myths and misconceptions about trauma; fact sheets on how trauma and abuse affect the brain; animated version of how the brain works for children; Surgeon General’s speeches highlighting this topic; teaching CD-ROM with discussion guide; fact sheet defining trauma, violence, and abuse and their prevalence.

The workgroup was presented with a list of seven topics from which to identify key priorities. They are listed in the box below.

Issues to Prioritize

1. Effects of early trauma (abuse, neglect, loss of a parent) on the development of depression and anxiety in women, especially on African-American women. [The group agreed to change this point to read: Mental health and developmental effects of trauma, abuse, neglect, and loss.]
2. Sexual violence against girls and women
3. Childhood abuse, whether physical or sexual, and its long-term effects
4. Domestic violence in heterosexual and same-sex relationships
5. Emotional abuse at any age
6. Effects of bullying, teasing, and sexual harassment in school
7. Sex and gender discrimination, sexual harassment, and violence in the workplace

### Defining trauma

There was considerable discussion based on this list regarding the need to broaden the definition of trauma, violence, and abuse to include things such as impersonal trauma (e.g., effects of war, natural disasters) and the impact of trauma, violence, and abuse on productivity, business, and the workforce. Similarly, several participants commented on the need to look at trauma, violence, and abuse within the cultural, historical, and political context of how and where they occur – not just as isolated incidents. They also considered the role of poverty as a context – though the group agreed that poverty was a mediating, not a causal, factor associated with these events.

“Providers don’t want to open that can of worms [assessing trauma, violence, and abuse], because they do not know how to deal with it and don’t have the referral services necessary. They need protocols to know how to ask the questions and deal with the fallout.”

—Breakout group participant

### Provider concerns

Another topic that generated a great deal of conversation centered on developing tools for providers to enable them to appropriately assess trauma, violence, and abuse. Participants noted that providers, particularly general practitioners, need a better understanding of how to ask questions about trauma, violence, and abuse and what to do with the answers – especially since they may be the only providers that consumers encounter. Several participants explained that there are many myths and misconceptions about how to deal with individuals who have suffered these events, and providers worry about such concerns as whether consumers will fall apart, how to develop a trusting atmosphere, and whether a provider should show emotional reactions. Participants expressed the need to develop tools and protocols that providers can use to deal with the fallout of a revelation of past trauma, violence, or abuse.

One participant noted that in her experience, it is easier to inform criminal justice workers about trauma, violence, and abuse than it is mental health professionals. Another participant added that it is not possible to train all providers to become trauma professionals. There are three levels of awareness regarding trauma: trauma aware, trauma sensitive, and trauma competent.

The group further reviewed the issues to prioritize to see if some could be eliminated or condensed. They discussed the need to add elder abuse and emotional abuse to the list of issues under the top priorities. Ultimately, the workgroup agreed to highlight the following three priority areas.

Key Priorities: Workgroup 3 Trauma, Violence, and Abuse

1. Developmental and mental health effects of trauma
2. Integration of health and mental health
3. Effects of emotional abuse

#### Key Priority #1: Developmental and mental health effects of trauma

##### Message

There was a great deal of discussion about defining a message for this priority area, starting with the need to define trauma. Other points that participants wanted to convey in the message touched on the idea that trauma harms us all, that recovery is possible and widespread, and that people who have experienced trauma should not feel ashamed or at fault.

Several participants commented on the fact that there is a lot of shame associated with being abused (or being an abuser) and that the message of this key priority would need to be reassuring, empathy building, and presented in a way that victims of abuse will not immediately reject.

The suggestion was made that the goal of the message should be to help change behavior, including for individuals at the precontemplative stage of change (i.e., those who have no intention of changing their behavior in the near future). One individual noted that the message needs to be brought to peoples’ doorsteps and shaped to resonate with the target audience. Thus, one angle that was suggested was to talk about safety and how violence, abuse, and trauma affect all aspects of our lives (e.g., how we work, how we learn, how we raise our children). In the end, the group agreed that the message should do the following:

- Define trauma
- Recognize the prevalence of trauma
- Convey the message that recovery is possible
- Use a common language that is directed to the individual and community level to take action
- Put a human face on trauma

##### Audiences

There was much discussion of potential audiences for a Surgeon General’s communiqué on violence, trauma, and abuse. Some of the suggestions included State mental health commissioners or governors, social workers, churches/faith-based organizations, individuals and communities, other sectors (e.g., business), and the general public. Eventually, the group decided to focus on two priority audiences:

- The general public (at the individual and community levels)
- Providers (from multiple sectors)

##### Format

The workgroup participants proposed that the format of this communiqué take the form of a two-step process:

Step 1: A letter from the Surgeon General to the general public addressing the centrality of trauma, violence, and abuse in women’s lives. It was suggested that this letter could go out to every household, similar to the Surgeon General’s letter on HIV/AIDS that was disseminated in the 1980s.

Step 2: A series of follow-up activities that could include PSAs targeted to specific audiences, toolkits, an Institute of Medicine (IOM) report on trauma, fact sheets on the myths and misconceptions about trauma, an emphasis on in-service training, and State trauma plans (as integrated into State mental health plans).

Many potential resources and models were cited by workshop participants to help guide the development of communiqués, including:

- The 1986 Surgeon General’s letter on HIV/AIDS
- Lessons from breast cancer campaign models
- A domestic violence campaign through hairdressers
- Real Men and Real Depression Campaign
- Trauma certificate program at the University of Maryland
- The Ohio business case on mental health report, soon to be released

“We never hear of a serious cancer, so why refer to a serious mental disorder?”

—Breakout group participant

#### Key Priority #2: Integration of mental health and overall health

The group discussed the question of how to address what some participants referred to as “a mind/body breakdown” – or the prevailing tendency to separate mental health and overall health in language, financing, service delivery, and common perceptions. The point was made that this separation increases stigma. The group grappled with developing suggestions on how the Surgeon General could address the issue of needing to integrate mental health more fully with overall health and stress the interoperability between the two.

##### Message

Numerous issues were raised during the discussion of how to frame a message, or several messages, related to the mind/body connection and importance of mental health to overall health. The first had to do with making the case for the connection and integrating the two as part of overall health. There was much discussion on the topic of the stigma associated with mental health. One participant noted the need to explain to people that there is a “range of normal or healthy behavior.”

Another suggestion was to look at the use of stigmatizing language associated with mental health issues; for example, one person commented, we never hear of “serious cancer,” so why refer to a “serious mental disorder?” Similarly, the point was made that the terms mental and substance use conditions carried less of a stigma than terms such as mental disorder and substance abuse. Ultimately, the group crafted the following messages related to addressing the mind/body dichotomy:

- Mental health is an essential part of overall physical health.
- There is no separation among the mind, body, brain, and behavior.
- There is a need to develop psychological literacy around the mind-body connection.

##### Audiences

Participants felt that communiqués should be developed for the general public as well as for providers from multiple sectors. In addition, workgroup members highlighted the importance of reaching out to particular age groups that may be traditionally underserved or left out. Specifically, the group proposed to focus on:

- Younger audiences (e.g., through Boys and Girls Clubs, 4H, etc.)
- Older adults, who may be particularly affected by issues of stigma and could benefit from more understanding about the mind-body connection

##### Format

Several ideas regarding formats were proposed, including:

- Fact sheets on how the brain works – on how psychosocial factors affect the brain and how that affects behavior
- An animated version of how the brain works for children and youth (e.g., the blue part of the brain reacts like this when this happens)
- An interactive video

##### Resources

The workgroup raised the question of how to leverage other groups that are addressing some of these mind-body issues (e.g., anger management).

#### Key Priority #3: Effects of emotional abuse

##### Message

There was considerable discussion regarding how to convey messages about the importance and severity of the consequences of emotional abuse, which some participants also referred to as “soul murder”.

Participants shared thoughts and concerns regarding the effects of emotional abuse – how it negates one’s existence, damages self-esteem, and can be as damaging as or worse than physical or sexual abuse. They also noted the difficulties of getting people to recognize the importance of emotional abuse; for example, one workgroup member commented that Child Protective Services will respond to cases of physical or sexual abuse but, when it comes to emotional abuse, will say that it “is not really going to stand up.” One person cited the work of Maxine Harris (e.g., Trauma Recovery and Empowerment: A Clinician’s Guide for Working with Women in Groups) as a good resource on the damaging effects of emotional abuse.

Workgroup members also talked about the role of emotional abuse in the context of sports. They discussed the need to train athletes to talk to kids and teach about rules and understandable lines that need to be respected. Participants noted the importance of teaching children and youth that you can act both aggressively on the field and respectfully off the field.

Although they found it difficult to define emotional abuse and craft succinct messages, the workgroup did come up with three key messages regarding emotional abuse, including:

- Emotional abuse is “soul murder.”
- Emotional abuse includes neglect, which is the “violence of silence.”
- Emotional abuse negates your existence.

##### Audiences

The following audiences were identified for messages relating to emotional abuse:

- Students
- Parents
- Older adults
- Coaches
- Teachers

##### Cross-cutting cultural concerns

Several workgroup members grappled with the question of how the definition and concept of emotional abuse may differ across diverse cultures (e.g., effect of spanking) and through the process of acculturation. They noted that there was a tension between what may be accepted in a particular culture and what may be personally damaging. As one participant commented, “Simply because something is accepted by a cultural group does not mean that it is right.”

The group discussed the importance of education, helping to identify what is abuse, and giving parents – including those who honestly believe that they are doing what is best for their child – an alternative that might be better. Participants also acknowledged the flip side of this type of awareness and education. For example, one workgroup member explained the risk of having a woman who suddenly learns that what she has been experiencing in her family is abuse but who is then disowned by her family, because they do not believe that their behavior toward her is inappropriate.

##### Dissemination

The group came up with numerous suggestions regarding strategies for disseminating messages about emotional abuse. These included:

- Having the Surgeon General include in his speeches that emotional abuse is a serious issue that needs to be addressed
- Developing a fact sheet including a definition of emotional abuse, prevalence, and examples
- Developing a film about emotional abuse
- Developing a CD-ROM teaching tool with a discussion guide
- Developing illustrative vignettes
- Getting these messages into pop culture (e.g., reality shows, Superman, etc.)
- Developing a list of how to identify emotional abuse for different age groups

Workgroup members also cited numerous opportunities that they saw for building on existing vehicles or venues to further disseminate messages about emotional abuse. These included:

- Building on the clearinghouse capacity of the newly formed Center on Women, Violence, and Trauma
- Increasing knowledge about what is already out there, such as existing clearinghouses and resources
- Developing an article (brief summary) about this Surgeon General’s Workshop on Women’s Mental Health that can be used for developing activities around women’s health month
- Developing a cadre of responders for the aftermath of crisis – possibly taking the form of a National Guard of Responders composed of individuals interested in helping to address trauma
- Supporting current leaders and developing emerging ones (e.g., on college campuses, in research positions at the NIH or the CDC) to carry the trauma message forward

Workgroup 3 Participants

Facilitators

A. Kathryn Power, M. Ed., Center for Mental Health Services, Substance Abuse and Mental Health Services Administration

Rene Andersen, M.Ed., Center on Women, Violence, and Trauma

Participants

Elizabeth Clark, Ph.D., M.P.H., ACSW, National Association of Social Workers

Susan Cochran, Ph.D., University of California, Los Angeles

Rachele Donnell, R.N., Red Lake Comprehensive Health Services

Rachel Fleissner, M.D., American Academy of Child and Adolescent Psychiatry and University of North Dakota

Joan Gillece, Ph.D., National Technical Assistance Center, National Association of State Mental Health Program Directors

G. Grijalva-Gonzales, Substance Abuse Services, San Joaquin County Health Care Services

Maxine Harris, Ph.D., Community Connections

Ruta Mazelis, Cutting Edge Newsletter, Sidran Institute

Pamela Mulder, Ph.D., Marshall University

Susan Nolen-Hoeksema, Ph.D., Yale University

Karen Peterson, M.D., Uniformed Services University of the Health Sciences

Rick Peterson, Ph.D., Texas A&M University, National Association of Rural Mental Health

Carole Warshaw, M.D., National Training and Technical Assistance Center on Domestic Violence, Trauma, and Mental Health

## Workgroup 4: Social Stress Factors and Stigma

Workgroup 4: Social Stress Factors and Stigma At-A-Glance

Priorities

1. Discrimination and stigma of women and girls who live with mental health issues
2. Depression and anxiety disorders among women and girls across the life span
3. The need to integrate mental health issues in settings where women and girls naturally congregate

Messages

- Discrimination is stigma. Stigma is compounded by factors such as sex and gender, culture, race, ethnicity, poverty, age, and locality.
- Stigma leads to lost opportunities.
- Women and girls have an increased level of suffering from mental health issues, associated with issues of family responsibility, poverty, employment, and access to mental health services.
- Having a mental disorder is not your fault and not something of which to be ashamed.
- It takes strength to reach out for help.
- Treatment works.
- Women and girls face unique risks at specific developmental stages (adolescence, pregnancy, postpartum, menopause, elderly years, etc.).
- Early intervention and identification promote greater success.
- It is important to distinguish between depression and normal sadness.
- Building knowledge helps to enhance access to identification and intervention.
- There is no health without mental health.

Products

Legislative breakfast, briefs with recommendations, PR materials, messages on commonly used products (e.g., diapers), bookmarks, cards, screening for moms when they bring children to the pediatrician, public transportation venues, school health curricula, first-aid approach, community networks, Web sites, workforce development, identifying champions, expanding State and national health weeks

The group was asked to consider and prioritize the list of six issues pertaining to social stress factors and stigma indicated in the box below.

Issues to Prioritize

1. Increased risk of victimization for all women
2. The extent to which lower socioeconomic status and/or immigrant status relates to mental health.
3. The discrimination and lack of social acceptance that those with mental disorders face
4. Internal barriers to seeking and receiving mental health care such as shame and guilt
5. Negative images of girls and women, particularly among minority women, in television, magazines, and film-related media
6. The need for additional research on the economic impact of maternal mental illness on family health outcomes

As the group reviewed the identified issues and addressed the task of trying to prioritize them, the discussion touched on several key themes, including stigma, cultural issues, and social stressors.

### Stigma

Much concern was voiced among members of the workgroup regarding aspects of our current mental health system that serve to reinforce issues of stigma surrounding mental health. For example, participants noted that the fragmentation of services, limitations on mental health coverage, and the lack of affordability of drugs to treat mental disorders contribute to stigma. The state of mental health treatment was characterized by one participant as “separate and unequal.” Discrimination was referred to as the “big elephant in the room,” and the argument was made that discrimination not only occurs in public mental health care but is in fact legally sanctioned in mental health. The resulting stigma and discrimination, it was noted, result in greater stress on individuals seeking help.

Several participants discussed strategies for getting messages out to the public to address and help reduce stigma. One concern specifically was in reaching families, who often expect to confront the challenge of mental illness alone and not discuss it with outsiders. It was suggested that there was a need to explain that mental illness is not just a family affair. One person noted, for example, that the literature on anxiety disorders suggests that these are biologically based illnesses. Explaining this to families helps them to understand that this is a medical diagnosis, just like heart disease, and should be seen as an illness that can be treated.

However, it was noted that describing mental illness as a function of genetics might prove offensive to an older population. The message “You have a real illness” seems to be more effective at addressing issues of shame, guilt, and stigma. Another participant suggested that there might be helpful “people first” language to be gleaned from the Institute for Mental Disease.

Participants also shared examples and ideas of ways to integrate mental health screening with other assessments to destigmatize the issue further. The example was raised of a screening assessment that included two trigger questions for mental illness listed with a series of other health screening questions, which reduces stigma. However, the point was made that once you screen a person for a mental disorder, you need to be able to refer them to appropriate information or treatments.

One participant explained that in Australia, information packets that include a suicide screening are given to every middle school student. Similarly, high school students receive a lunch kit with information on mental health agencies, birth control resources, drug issues, and other information – the point being that the widespread dissemination of this information helps reduce stigma and increase awareness.

### Culture

Language barriers coupled with a lack of cultural sensitivity by providers were cited as a significant challenge to overcoming stigma in some communities. Participants noted that it would be important to have some background information on different issues regarding social stress factors and stigma within different cultures. Another related comment was that consideration needs to be given to individuals who are minorities but foreign born – a population which is often overlooked. This may require developing targeted materials for specific communities, as several group members noted, that are not simply a translation or adaptation of materials developed for the “mainstream” population. It was recommended that materials be developed from the ground up to reflect specific cultures and cultural issues.

Other participants cautioned that diversity should not be focused solely on race or ethnicity, but also on issues such as sexual orientation, geography (e.g., underserved rural or urban environments), and age groups (e.g., children). Several people commented that one consumer may belong to many groups and that emphasis should be placed on starting with one core message that resonates across many sociocultural strata.

### Social stressors

The workgroup spent time identifying social stressors that might affect women’s mental health, their resilience, their ability or willingness to seek help, and their outcomes. The list of issues they compiled included:

- Poverty
- Homelessness
- Being uninsured or underinsured
- Lack of knowledge regarding mental illness or substance abuse
- Living in a rural environment
- Living in the inner city
- Isolation
- Incarceration
- Living in the projects
- Aging
- Immigration (e.g., guilt, trauma history, acculturation)
- Racism
- Lack of long-term coverage for treatment

After creating this broad list of social stressors, the group turned its focus toward identifying those factors that are of particular concern to women. This list included:

- Women acting as primary caregivers for family members
- Stigma for women associated with substance abuse
- Stigma for women associated with loss of child custody due to mental health issues
- Girls with a mentally ill parent tend to take on caregiver roles
- In the caregiver role women have little time for self-assessment
- Peer pressure for girls (e.g., smoking, the “mean girl” phenomenon)
- High rates of victimization for both women and girls
- Negative images, especially of minority girls and women
- Women and girls having different mental health issues

The power of public health education, it was noted, should not be underestimated. Workgroup members shared examples of positive campaigns or changes that could serve as models. One example given was of a generation of children who have been taught to cough into their arms instead of their hands. Another example that was highlighted was of the effectiveness of the seat belt safety message – largely because it has been translated into law.

Several issues were discussed but ultimately placed in a “parking lot” for future consideration. These included:

- Trafficking of women
- Single-payer systems
- The state of mental health care in the United States
- Parity
- Housing

Based on their long discussion and consideration of priorities, the workgroup identified three priority issues, presented in the following box.

Key Priorities: Workgroup 4 Social Stress Factors and Stigma

1. Discrimination and stigma of women and girls who live with mental health issues
2. Depression and anxiety disorders among women and girls across the life span
3. The need to integrate mental health issues in settings where women and girls naturally congregate

#### Key Priority #1: Discrimination and stigma of women and girls who live with mental health issues

##### Message

Following their lengthy discussion on discrimination and stigma, the workgroup members agreed to highlight the following messages:

- Stigma is discrimination. It is exacerbated by factors such as sex and gender, race and ethnicity, poverty, age, and locality (e.g., rural, inner city).
- Stigma leads to lost opportunities.
- Women and girls have an increased level of suffering from mental health issues, associated with issues of family responsibility, poverty, employment, and access to mental health services.
- Having a mental disorder is not your fault and not something of which to be ashamed.
- It takes strength to reach out for help.
- Treatment works.

##### Audiences

The group members identified the following audiences for this priority issue:

- Policymakers
- General public – including schools, faith-based organizations, etc.
- Primary care providers
- Families
- Service utilization sites

##### Format

The group noted that the Health Resources and Services Administration (HRSA) is already in the process of developing a toolkit related to women’s mental health for primary care settings. The suggestion was made that if resources are limited, it would be important to focus on areas of high risk or service-based programs, such as the Supplemental Food Program for Women, Infants, and Children (WIC).

Some of the recommendations for formats focused on reaching a general public audience. Suggested formats included:

- Age-appropriate pamphlets
- Messages in school planners
- Word of mouth
- Ways to get into the media
- Web-based formats for younger audiences
- Radio-based formats for older audiences

Another suggestion with regard to targeting policymakers was to try to come up with formats and materials that could show the economic benefits or cost-benefit analysis of addressing stigma and discrimination to promote greater understanding, prevention, and treatment of mental health issues.

A final suggestion was to look at existing resources and ways to help disseminate or integrate those further.

##### Cross-cutting cultural concerns

Participants identified cultural barriers related to discussing “problems” with someone of another culture, race, or ethnicity. They also noted the importance of addressing cultural barriers within a community that contribute to misunderstanding, stigma, and discrimination.

#### Key Priority #2: Depression and anxiety disorders among women and girls across the life span

##### Message

The group developed several messages related to this priority area:

- Women and girls have unique behavioral health risks at specific developmental stages. Examples include adolescence, pregnancy, postpartum, menopause, and elderly years.
- Early intervention and identification promote greater success.
- It is important to distinguish between depression and normal sadness.
- Building knowledge helps to enhance access to identification and intervention.

##### Audiences

The workgroup members focused on several specific audiences for this topic and set of messages, including:

- Primary care family practices
- OB/GYNs
- Pediatricians
- Schools
- Sororities and other college-based organizations

##### Formats

The workgroup members suggested the following formats for conveying the messages, including:

- Putting messages on commonly used products, such as diapers, formula, etc.
- Bookmarks, cards (high school, college)
- Screening for moms when they bring their child to the pediatrician
- Putting messages on public transportation venues (e.g., bus shelters)

##### Cross-cutting cultural concerns

Participants identified several cultural concerns. One had to do with addressing the culture of silence surrounding depression and mental disorders generally, particularly within diverse racial, ethnic, or cultural groups. A related issue was the role of traditional practices and values with regard to depression and anxiety disorders. Another concern was the fact that depression and mental disorders are seen as a family issue in some cultures, one that needs to be kept within the family sphere – thus discouraging individuals from seeking treatment.

#### Key Priority #3: Failure to integrate mental health issues in settings where women and girls are

##### Message

The workgroup crafted a very simple message to address this priority issue:

There is no health without mental health.

##### Audiences

They identified numerous audiences:

- Schools
- Primary care physicians
- People in all health-related disciplines
- Faith-based organizations
- Community-based organizations, such as scout groups, the Rotary Club, and the League of Women Voters
- Public education students (pre-K through grade 12)
- Stores, barber shops/beauty parlors, clinics, and local hangouts

##### Formats

The suggested formats included:

- A first-aid approach (psychological first-aid for children already exists)
- A school health curriculum
- A community-based campaign within social networks
- A Web site
- Workforce development
- Toolkits
- Champions within the community
- Mentors
- Health advocates
- Identified health weeks or health days

##### Cross-cutting cultural concerns

The group discussed issues of language: how the message is framed, by whom, and whether or not it is in a person’s mother tongue. The suggestion was made that diverse consumers should be involved in the development and implementation of communiqués to ensure greater cultural competence. They also pointed out the need to address issues related to persons with physical disabilities.

Workgroup 4 Participants

Facilitators

Teresa Chapa, Ph.D., M.P.A., Office of Minority Health, Office of Public Health and Science, DHHS

Kinike Bermudez-Walker, National Asian American Pacific Islander Mental Health Association

Participants

Alan Allery, Ph.D., M.H.A., M.Ed., University of North Dakota School of Medicine and Health Science

Belinda Biscoe, Ph.D., University of Oklahoma, College of Continuing Education

Jerilyn Cohen-Ross, M.A., LLCSW, Anxiety Disorders Association of America

Larke Huang, Ph.D., American Institutes for Research

Jean Lau Chin, Ed.D., Alliant International University Carmen Lee, Stamp Out Stigma

Richard M. Lerro, M.L.A., Eating Disorders Coalition

Jacki McKinney, M.S.W., Center on Women, Violence, and Trauma

Dennis Mohatt, Western Interstate Commission on Higher Education

Lisa Najavits, Ph.D., Veterans Affairs, Boston Healthcare System

Jon Perez, Ph.D., Indian Health Service

Lincoln Stanley, M.A., American Association for Marriage and Family Therapy

## Workgroup 5: Identification and Intervention Issues

Workgroup 5: Identification and Intervention Issues At-A-Glance

Priorities

- 1. Preventive interventions for the most common and disabling disorders, such as major depression and anxiety
- 2. The need for screening for depression, anxiety, and other common mental disorders in primary care, schools, and other settings
- 3. The importance of consumer and provider empowerment, self-determination, and choice in mental health treatment

Messages

- The concept of mental health must be broadened to include other systems (e.g., primary care, education, employment, housing). It also should use a strengths-based approach, highlight prevention as the beginning of the continuum of care, and expand the scope of services across generations and from individuals to families.
- Identify and develop holistic screening tools to assess mental disorders.
- Community involvement is needed to establish a process of empowerment and self-determination.
- Barriers (language, culture, costs) must be removed to empower consumers and providers. Federal agencies (e.g., Health, Education, Justice, Labor) can help remove these barriers.
- A collaborative care strategy is needed to overcome financial and administrative silos.

Products

Community partnerships with health care, employers, schools, managed care organizations, insurers, and peer support groups; community toolkits with examples of effective tools, reviews of the latest science; education protocol on how to use assessment tools; identify champions to promote use of assessment tools; consumer education communiqué; toolkit for advocacy and community mobilization; intergenerational worksheet to manage mental health issues; local mental health care decision making flow sheets (like those of Cancer Regional Centers); storytelling approaches; address issues for immigrant women and families

The key priority issues assigned to this workgroup are listed in the box below.

Issues to Prioritize

1. The importance of consumer and provider empowerment, self-determination, and choice in mental health treatment
2. Models for transitioning women from institutions to re-entry into family and community living
3. Preventive interventions for the most common and disabling disorders, such as major depression and anxiety
4. Depression and anxiety that go undiagnosed and therefore untreated
5. The need for screening for depression, anxiety, and other common mental disorders in primary care, schools, and other settings
6. The need to implement the comprehensive nationwide program for suicide prevention previously described in the National Strategy for Suicide Prevention
7. The lack of support and care options for older women
8. Complementary and alternative medicine in relation to self-treatment of mental disorders

As members of the workgroup considered how to identify the top three priority issues they also identified a number of related issues that affect the diagnosis and treatment of women’s mental disorders. Those issues are grouped here according to common themes:

### Target populations

- Older populations, especially their growing demographics and rising rates of responsibility in raising grandchildren
- An increasing number of women who are foreign born and the lack of a support system for them, especially the elders

### Access to and funding for mental health services

- The role of insurance companies in empowering or disempowering providers in their ability to provide care
- Health economics and the waste of health care dollars when alternative practices are not validated
- Access to care – mental health being seen as an additional burden rather than as a critical part of care
- The need for education, interagency coordination, and less fragmentation that contributes to underdiagnosis and mistreatment of mental disorders
- Bringing care into the home (helps address barriers)

### Treatment issues

- Choosing one’s own path to health, reducing isolation, and increasing networking opportunities
- Treating individuals versus working with the family unit
- The sense that believing in treatment can help to make it more effective
- The need to promote community-driven supports
- Faith-based activities

### Prevention

- Preventive efforts are critical to improving health status but are not well funded.

### Provider education and training

- Training and education – the need to shift how and whom we train
- The lack of minority health providers

Of the issues presented to the group, the following three were chosen as the top priority issues.

Key Priorities: Workgroup 5

1. Identification and Intervention Issues
2. Preventive interventions for the most common and disabling disorders, such as major depression and anxiety
3. The need for screening for depression, anxiety, and other common mental disorders in primary care, schools, and other settings
4. The importance of consumer and provider empowerment, self-determination, and choice in mental health treatment

#### Key Priority #1: Preventive interventions for the most common and disabling disorders, such as major depression and anxiety

##### Message

Members of the workgroup argued that the concept of mental health needed to be broadened to take into consideration other systems, such as primary health care, education, employment, and housing. They emphasized the fact that mental health affects and is affected by these systems.

The group also identified the following attributes of a message for this topic:

- Uses a strengths-based approach
- Highlights prevention as the beginning of the continuum of care
- Expands the scope of services across generations and from individuals to families

##### Audiences

The identified audiences included:

- The entire health care system, especially the primary health care system
- Schools
- Employers
- Insurers, especially managed care
- Community-level organizations
- Self-help groups

##### Formats

The group suggested the need to create community partnerships with health care, employers, schools, managed care, insurers, and peer support groups. Participants noted that it would be important to establish a knowledge base within the community to help recognize prevention and resilience issues. Two other suggestions were that treatment must connect women in care to other systems options and that community involvement in the intervention process should be developed and enhanced.

##### Cross-cutting cultural concerns

The following cross-cutting cultural concerns were raised:

- Recommendations must be community driven and developed by stakeholder partners.
- Consideration of self-directed complementary and alternative treatments should be integrated into the development of communiqués and toolkits.

#### Priority Issue #2: The need for screening for depression and other common mental disorders in primary care, schools, and other settings

##### Message

For this topic, the group came up with the following message:

Identify and develop holistic screening tools for the assessment of mental disorders.

In discussing the message, the suggestion was made that there was a need to create tools that measure the “whole woman.” The example was offered of the Medical Outcomes Study Short-Form 36 (SF-36), which has been extensively tested and validated and is a functional health self-assessment measure with physical and mental health scales. It measures mental-component-improved-scores by (1) antidepressants and (2) self-described behavior changes (spiritual growth, dealing with relationships, doing work they are good at what matters, taking care of themselves). It was explained that the process of using a simple tool to identify mental health issues helps patients feel listened to and holds providers accountable to dealing with these issues and suggesting interventions.

Other participants discussed the need to establish functional health measurements that ask the right measurement questions. Also noted was the need to create a structure for mental health measurement and response that can be integrated and standardized into current practices, especially in primary care practice. Group members noted the importance of interpreting the numbers and being able to “translate the numbers back into people.” The suggestion was made that tools be adapted to the unique needs of diverse populations or providers through methods such as demonstration programs, which also would test their functionality in a “living laboratory” or real world setting.

One participant raised the issue of developing broadly based, holistic screening tools that could empower consumers (e.g., self-assessment tools) and promote access to services. These types of tools would need to focus on functionality and quality of life, it was explained, rather than simply on symptom reduction. They also would need to be culturally and developmentally appropriate.

Another key point of discussion was the need for identified referral systems and services to follow up on screenings and assessments. Participants pointed to the importance of education and training to properly use assessment tools – and to avoid bias and discrimination based on health-related stereotypes. As one person noted, “the tool is only as useful as the training on how to use it properly.” One suggestion was the possibility of developing a training manual to describe the process of using an assessment tool. As a final comment, one workgroup member noted that assessment tools can be important for securing funding.

##### Audiences

The suggested audiences for this message were:

- Federal agencies
- Funders
- Schools
- Providers
- Consumers

##### Formats

The following suggestions were made regarding potential formats:

- Community-based and tested toolkit. Workgroup members discussed the need to gather information to develop or find existing assessment and screening tools. As part of this process, they proposed the development of a toolkit that identifies such things as examples of effective tools and reviews of recent scientific research on this topic.
- Educational protocol. The group identified the need to train providers on how to use assessment tools tailored to the specific needs of women, especially those of color. The training and curricula would need to be culturally and linguistically appropriate, relevant, and sensitive, and it would need to include training in self-assessment techniques. The training should be field-based and able to highlight how these tools work in real-life settings.
- Something that gathers information on the importance of using these tools and how it can improve women’s mental health outcomes. This would be designed to inform stakeholders.
- Champions. Identifying individuals to champion the use and integration of tools within communities. It was noted that champions can be found often in times of tragedy.

##### Cross-cutting cultural concerns

The group underscored the importance of community-driven involvement in the development of materials. This was defined as including the active involvement of community-based organizations and individuals from both within and outside of mental health. It was noted that stakeholder partnerships should be established and include a reciprocal communication of ideas. The need for culturally and linguistically appropriate training on the use of assessments was also re-emphasized as part of this discussion.

##### Challenges

Along with their recommendations, workgroup members identified a series of challenges, including:

- How to respond to the mental health issues that are identified by assessment tools
- How to identify which types of activities and treatments have worked and will work for patients
- How to establish an adequate supply of providers to whom you can refer patients

“We don’t just want to be at the table; we want to eat at the table.”

– Workgroup member and consumer representative

#### Key Priority #3: The importance of consumer and provider empowerment, self-determination, and choice in mental health treatment

There was some disagreement regarding the phrasing of this priority issue. Several participants expressed the concern that the concept of mental health needed to be broadened to include the wider context in which women’s mental health plays out. There was also interest in including the concept of self-directed care. One other suggestion was to include this sentence: “Mental health care strategies include alternative and complementary treatment options.”

Ultimately, the priority was left as indicated.

##### Messages

The following messages were recommended by the group:

- Community involvement is necessary to establish a process for empowerment and self-determination. As one participant noted, “We don’t just want to be at the table; we want to eat at the table.”
- Health systems and Federal agencies (e.g., the Departments of Health and Human Services, Education, Labor, and Justice) should help remove barriers (e.g., language, cultural, financial) to consumer choices and empowerment.
- A collaborative care strategy (e.g., substance abuse and mental health) is necessary to overcome financial and administrative silos.

##### Audiences

Workgroup members identified a broad array of audiences for this topic, including:

- The entire health care system
- Schools
- Employers
- Insurers
- The community
- Self-help groups

##### Formats

The following formats were suggested:

- Consumer education communiqué for consumers, providers, and advocates
- A toolkit on advocacy and community mobilization for empowering women
- Intergenerational worksheets and plans of management for mental health issues, with separate worksheets for different population groups, providers, consumers, and policymakers
- Toolkits for immigrants and refugees about their rights and explaining the basics about the mental health treatment system, making legal provisions accessible to vulnerable populations
- A local mental health care decisionmaking flow sheet, perhaps similar to one developed by the Cancer Regional Centers
- A Surgeon General’s Call to Action, to pull in representation from all stakeholders to make recommendations happen

Several comments regarding formats touched on the idea of using nontraditional communication methods, such as a storytelling approach.

“Mental health is not an individual issue. It affects whole communities and is partly caused by the broader community. Women are complex, and they require a complex strategy to address all of their nuances.”

—Breakout group participant

##### Challenges and strategies to overcome them

The workgroup cautioned that communiqué development would need to anticipate challenges and resistance to holistic concepts and the use of terms such as “living laboratories” that are unfamiliar to more mainstream communities, such as policymakers and planners, training institutions, mental health centers or authorities, school districts, and such.

To address these challenges, members of the workgroup proposed the following:

- Invite stakeholders who may be potential sources of resistance to participate in the decisionmaking process.
- Develop clinical Centers of Excellence for Women’s Mental Health. These could be national, State based, county based, Tribe based, university based, or special populations based.
- Develop structures to organize community-based groups, including faith-based groups, around women’s mental health that operate outside of clinical Centers of Excellence. There may be opportunities to create pilot projects at this level as well.
- Create “living laboratories”, pilot projects, or “transitional research” to initiate this process. Start small to see how they work, and expand them if they do well. The ultimate goal is to make new initiatives standard in current practice. An example of a “living laboratory” could be a recovery group.
- Develop a sex and gender focused national effort focused at the State level to address mental health issues (e.g., trauma) by developing State-level leadership (e.g., governors and their spouses, State mental health directors, State Medicaid directors).
- Identify women’s mental health champions.

##### Further priority issues from the group

As a wrap-up to their workgroup discussion, participants went around the table and identified their own priority issues:

Focus on specific women’s mental health issues, such as older women’s issues, perinatal depression, and substance abuse issues.

- Focus on agencies and organizations (e.g., medical, social worker) that can think about and mobilize on these issues.
- Develop practical tools in a way that makes practitioners, consumers, and others want to grab hold of them and use them.
- Mobilize serious resources to improve training and workforce development as a way to improve quality of services for women.
- Think more fully about how to reach nonmedical providers and providers of alternative or complementary medicine.
- Focus more energy on prevention at early ages with ways to strengthen girls and young women. Remove stigma and begin empowerment regarding mental health early in life. Blend these efforts across generations within communities.
- Use existing leadership and develop future leaders, recognizing the capacity of underutilized advocates.
- Increase the level of communication and build bridges between communities.
- Address mental health issues through a life span approach, and recognize that providers have their own mental health issues.
- Take a serious look at sources from which future funding will come.
- Consider women’s mental health within the complex context of their lives.

Workgroup 5 Participants

Facilitators

Susan E. Salasin, Center for Mental Health Services, SAMHSA

R. Dale Walker, M.D., Ph.D., Oregon Health and Science University

Participants

Evelyn Becker, Ph.D., Indian Health Service Dwana Bush, M.D., Center for Integrative Health

Vickey Coffey, M.S.A., Chicago Metropolitan Battered Women’s Network

Deborah Donaldson, Sedgwick County NACBHD

Yoon Han, M.Ed., M.S.W., Asian Counseling and Referral Service

Pablo Hernandez, M.D., American Institutes for Research

D.J. Ida, Ph.D., National Asian American Pacific Islander Mental Health Association

Luella Klein, M.D., American College of Obstetricians and Gynecologists

Denise Laine, Ph.D., National Jewish Medicinal and Research Center and American Academy of Nurse Practitioners

Joanne Nicholson, Ph.D., University of Massachusetts Medical School

Paulette Running Wolf, Ph.D., First Nations Behavioral Health Association

David Takeuchi, Ph.D., University of Washington

Katherine Wisner, M.D., M.S., Western Psychiatric Institute and Clinic, University of Pittsburgh Medical Center

## Workgroup 6: Treatment Access and Insurance

Workgroup 6: Treatment Access and Insurance At-A-Glance

Priorities

1. Effects of racial, ethnic, and linguistic disparities in health service access, data, evaluation, and delivery on mental health status
2. Access to appropriate and effective care through primary care providers, mental health specialists, and nonclinical settings
3. Financial and structural barriers – including insurance coverage, reimbursement policies, and mental health parity

Messages

- Include and know your community.
- Disparities come at a high cost to society.
- Everyone can do something to eliminate racial and ethnic disparities.
- Health care providers and lay workers are key to eliminating disparities, but they need specific tools and support.
- We need 100% access and must build capacity for “no wrong door”.
- Integrate mind, body, and soul. We should use a holistic approach, based on the biopsychosocial model.
- What every woman should know about mental health care…
- Access to appropriate care is a woman’s right.
- Women’s health is funda-MENTAL.
- Lack of parity for mental health coverage affects our future human and economic resources and costs society.
- Society gains when effective and accessible mental health care is available.

Products

Toolkits for health care and lay providers; assessment tools; consumer-based DVDs in pediatric offices, nail salons, consumer groups; PSA, profiles of best employers and insurers that promote and address mental health; State Report Cards on mental health; communiqués for employers that make the business case for mental health; Web-based CEUs.

The key priority issues assigned to this workgroup are listed in the box below.

Issues to Prioritize

1. Access to appropriate care through primary care providers and mental health specialists
2. The effects of racial and ethnic disparities in health service access and delivery on mental health status
3. Lack of parity for mental health care coverage
4. Insurance coverage
5. Competing demands for women that limit their ability to access care (e.g., taking care of children and other relatives)
6. Better access to treatments for adolescent depression, anxiety disorders, and eating disorders
7. Access to sex and gender appropriate diagnostic and treatment services
8. The lack of culturally and linguistically competent providers and treatment materials

The group considered and commented on each of these issues in order.

1. Access to appropriate care through primary care providers and mental health specialists
  Here the point was raised that most people go to doctors, not mental health specialists. Thus, there is a need to learn how to integrate mental health concepts into primary care – creating a seamless system between the primary care physician and mental health services. It was noted that even if physicians know how to help deal with mental health issues, they lack the time in a typical office visit. In addition, appropriate care is not always there – particularly to address sex and gender, culture, and age specific issues, and it is important that care be not only appropriate but also effective.
  The need to look at best practices was raised, with the comment that although primary care doctors have the reputation for being uncomfortable with mental health issues, there are models out there for doctors to cover it better. The problem is that these models are not well-disseminated or widely used.
  It was noted that consumers do not always have a choice regarding the type of provider they can see. The suggestion was made that we need to look at the full continuum of care, including personal, family, and community roles and resources. Following the continuum to the end, noted a workgroup member, also means caring for the provider, who is vulnerable to stresses and mental health issues as well.
2. The effects of racial and ethnic disparities in health service access and delivery on mental health status
  The workgroup members agreed that disparities should be considered as an overarching issue that reaches across multiple topics listed among the priority issues.
3. Lack of parity for mental health coverage
  The discussion of this topic began with the question of how to define parity. One comment was that the issue of lack of affordable and effective insurance coverage combines lack of parity for mental health coverage with issues of insurance coverage. There was some discussion about whether these are different issues or should be combined. An additional topic that was raised regarding parity concerned the question of medical codes driving what types of things doctors do during visits.
4. Insurance coverage
  One point raised related to this topic was that there is sometimes a lack of understanding regarding insurance coverage – that some people may have coverage but not understand what is covered. This was seen as an issue that needed to be more fully understood at a community level – understanding coverage and how to get treatment. Participants commented on the fact that there are differences in coverage across the country and that within a given State, there are varying levels of access to care among groups such as undocumented immigrants or members of particular racial and ethnic groups.
5. Structural barriers were noted, as were provider incentives from insurance companies or accreditation bodies to use particular screening tools.
  Competing demands for women that limit their ability to access care (e.g., caretaking of children and older relatives)
  Participants recognized the need for actionable and practical solutions to address the issue of competing demands and sex and gender roles. One suggestion was to focus on nonclinical settings, such as self-care, that may be easier to fit into women’s lives. Other ideas included involving schools, churches, Head Start, and similar programs or organizations to fit into women’s multiple constraints and responsibilities. One commenter noted that the group should not focus only on mothers.
  A further suggestion was to encourage more girls and women to go into health professions to increase the supply of providers who are potentially more culturally competent and sensitive to sex and gender differences.
6. Better access to treatments for adolescent depression, anxiety disorders, and eating disorders and
7. Access to gender-appropriate diagnostic and treatment services
  These two topics generated little discussion other than to consider where these types of services are delivered.
8. The lack of culturally and linguistically competent providers and treatment materials
  Suggestions for addressing this topic included looking at how to train providers to deal with cultural stigma, addressing provider-patient communications, and exploring examples of culturally appropriate best practices.

“Mental illness does not discriminate, so why does the health care system? As a result, women are disproportionately affected.”

—Breakout group participant

### Other topics

Several other topics were considered during this discussion. These included the following:

- Developing tools to address how consumers should talk with providers and what was the best use of time during an office visit.
- The need for more information on what resilience is and how to support good mental health during the primary care visit. The need for wellness and prevention models for mental health was highlighted.
- Further exploration of nonclinical models, such as self-care. For example, patient care management through the Internet has been shown to be effective.
- The need for toolkits to address financial issues (getting health care, including mental health services), integrated care issues (what to expect from a primary care provider on an annual visit), and health disparities/cultural competence.

To reflect the richness of the discussion, the group proposed to highlight several overarching issues as a preamble to their list of top priorities. Those overarching issues include:

- The incorporation and involvement of women, following the theme: for the community and by the community.
- Culture must be considered very broadly, including not only race and ethnicity but also sexual orientation, disabilities, life span, socioeconomic position, geography, and religious context.
- We must make the business case for the high cost of disparities for each priority area.
- We must recognize the importance of public discourse and the media for fostering a national dialogue and use these to create new expectations for women’s mental health.

The workgroup members voted to identify the top priority issues and easily identified three as the most important and overarching, with several others seen as fitting under them. Some of the wording was revised to expand or define the issues more clearly, resulting in the three highlighted in the box below.

Key Priorities: Workgroup 6 Treatment Access and Insurance

1. Effects of racial, ethnic, and linguistic disparities in health service access, data, evaluation, and delivery on mental health status
2. Access to appropriate and effective care through primary care providers, mental health specialists, and nonclinical settings
3. Financial and structural barriers – including insurance coverage, reimbursement policies, and mental health parity

#### Key Priority #1: Effects of racial, ethnic, and linguistic disparities in health service access, data, evaluation, and delivery on mental health status

##### Messages

The following messages were articulated by the group:

- Include and know your community. Participants emphasized the importance of including experts from the community and of being trained by people from the relevant culture, racial group, ethnic group, or gender orientation. In addition, they argued that there was a need to include the appropriate data and evaluation tools – developed with the input of the appropriate cultural perspective.
- Disparities come at a high cost to society. Emphasize and demonstrate the high cost of disparities to society (e.g., DALY metric).
- Everyone can do something to eliminate racial/ethnic disparities.
- Health care and lay providers are crucial to eliminating racial/ethnic disparities, but they need support and specific tools to do so. Tools exist, as do referral sources and community resources, but they must be more effectively identified and used.

One person noted that mental illness does not discriminate, but the health care system does. As a result, she added, women are disproportionately affected.

##### Audiences

The group identified the following audiences, noting that these would vary depending on the particular message:

- Providers, including lay providers (messages such as “Know your patients, and know what to tell them”)
- Elementary through high school youth
- Policymakers (messages on such topics as costs of health disparities)
- General public (messages such as “Disparities do not discriminate; why does the health system?”)
- Consumers (messages that help empower them)

##### Formats

Workgroup members felt that messages for the consumer should be empowering and help them to talk with their provider. However, the concern was raised regarding how to get people to listen to these messages. This was recognized as the challenge with recommending formats. One participant suggested looking for good models and pointed to the example of the Primary Prevention toolkit that came out about 10 years ago (possibly from the Office of the Surgeon General), which included stickers, folders, and other freebies.

Their suggested formats included:

- Toolkits for providers (supports to eliminate disparities) to be used for provider certificates and training
- Communiqués aimed at businesses, insurance companies, and policymakers highlighting the high costs of disparities

##### Cross-cutting cultural concerns

Members of the workgroup suggested that culture should be considered very broadly – not just race and ethnicity, but also life span, sexual orientation, disabilities, socioeconomic status, living in rural areas, and religious context (as mentioned in Healthy People 2010).

#### Key Priority #2: Access to appropriate and effective care through primary care providers, mental health specialists, and nonclinical settings

##### Messages

The group articulated the following messages:

- 100 percent access. The group’s primary message was that access must be universal, which in turn would lead to zero disparities.
- Integrating mind, body, and soul. A holistic approach was advanced, using the biopsychosocial model and integrating the delivery of care to address the whole person.
- What every woman should know about mental health. This includes a “navigator” theme, which has been used successfully in the cancer community to help consumers navigate the health care system to obtain the services, information, and treatment they need. This message also includes the idea that every woman should have some basic wellness/prevention tools.
- Access to appropriate care is a woman’s right. Everyone should have access to at least one effective intervention for his or her particular diagnosis, issue, problem, or health care concern.
- Women’s health is funda-MENTAL. Access barriers to services and care may vary by individual, community, or context, so you need community participation and partnership to identify, prioritize, and rectify barriers. We need an integrated system that connects primary care providers and mental health providers that can offer culturally, racially, and ethnically appropriate best care practices.

##### Audiences

Two key audiences were identified for these messages: providers and consumers.

##### Formats

The group’s suggested formats included the following:

For consumers

- An educational DVD offered in pediatric offices, food stamp programs, churches, beauty shops, gyms, and other venues where women can be reached. It would address the life span, contemplate different groups of women, and provide role models. It also would address navigation issues such as how to access treatment, which treatments are available, and so forth.
- PSAs for radio and TV stations

For providers

- CEUs and conferences to build capacity through integrated treatment. Emphasize access to care in clinical and nonclinical (peer support groups, etc.) settings that focus on prevention, wellness, and care using the biopsychosocial model. Dissemination must recognize the challenge of getting providers to read materials, which can be addressed through strategies such as CE courses or Web-based information.

#### Key Priority #3: Financial and structural barriers – including insurance coverage, reimbursement policies, and mental health parity

##### Messages

These were the messages articulated by the workgroup regarding the issue of financial and structural barriers:

- Lack of parity for mental health coverage affects our future human and economic resources and costs society.
- Society gains when effective and accessible mental health care is available (e.g., low employee turnover, increased productivity, less need to hire and train new employees).

The point was made that it was important to show data demonstrating the cost benefits of mental health coverage to employers, insurers, and policymakers.

Another issue raised during this discussion was the importance of ensuring that coverage takes into account the caregiver role, primarily played by women, and gives assistance in navigating the system.

##### Audiences

The identified audiences for these messages included employers, payers (insurers), and policymakers.

##### Formats

Suggested formats included:

- A toolkit or communiqué for businesses showing the business case for offering mental health coverage
- Media partnerships
- Profiles of employers offering the best mental health coverage and services (e.g., report card, best companies to work for, incentives)
- A report card of State coverage and services for mental health

Workgroup 6 Participants

Facilitators

Jane Wilson, M.S., Office of Public Health and Science, DHHS

Vickie Mays, Ph.D., M.S.P.H., University of California-Los Angeles

Participants

Margarita Alegria, Ph.D., Cambridge Health Alliance, Harvard Medical School

Thelma Baskin, Kansas City

Angeline Bushy, Ph.D., R.N., University of Central Florida

Lorraine Cole, Ph.D., National Black Women’s Health Imperative

Kathleen DeBold, B.S., The Mautner Project

Rani Desai, Ph.D., M.P.H., American Public Health Association, VA Connecticut Healthcare System

Carmen Inoa-Vazquez, Ph.D., Bellevue Hospital Center

Oscar Morgan, M.A., National Mental Health Association

Shirley Repta, Ph.D., M.B.S., APRN, B.C., American Psychiatric Nurses Association

Catherine Shisslak, Ph.D., University of Arizona College of Medicine

Nancy C. Speck, Houston, TX

Sharon Sweede, M.D., American Academy of Family Physicians

Workgroup 7: Health System Issues At-A-Glance

Priorities

1. Medication issues for women
2. Inadequate emphasis on women’s mental health issues in education and training for health care providers
3. Family planning and women with major mental illness

Messages

- Additional evidence-based information is urgently needed concerning the safety and effectiveness of psychotherapeutic medications, including sex and gender and reproductive cycle factors and consideration of nonpharmacological interventions.
- Women’s mental health needs should be incorporated into all levels of health care curricula, including in the knowledge, skills, and attitudes regarding sex and gender differences and issues of race, ethnicity, and culture.
- Discussions about reproductive health and family planning should be incorporated into the care of all women with major mental illness.

Products

PSA, booklets, proclamation, posters, RFPs, Web-based CEUs, advocacy toolkit, letters to governing bodies of educators, press releases

## Workgroup 7: Health System Issues

The list of priority issues to be considered by the health system issues breakout group is identified in the box below.

Issues to Prioritize

1. Lack of information on safety, dosing, and effectiveness of medications during pregnancy and lactation
2. Inclusion of women in clinical trials and pharmacokinetics/pharmacodynamics of drugs
3. Inadequate emphasis on women’s mental health issues in academic curricula for physicians and other health care professionals
4. Side effects of medication
5. The role of hormone therapy in symptomatic perimenopausal women
6. Family planning and women with major mental illness

There was considerable general discussion on the topic of health systems issues prior to consideration of how to prioritize the ones presented to the group.

### Budget constraints

Budgetary concerns at the State and provider system level were identified as one problem plaguing the health care delivery system. As one provider put it, “Money and budget undercut all of the issues in this group.” Similarly, fragmentation in the system itself was identified as an important barrier along with the lack of agreement on how to deliver mental health care; for example, whether it should be focused more on pharmacology or nonpharmacological issues.

### Technology transfer

However, the primary concern for many group participants, which was not listed as a priority, was the issue of technology transfer – or how to transfer knowledge from research and the evidence base into language and tools that would be beneficial to consumers – especially those, like homeless women, who are most at risk. The group suggested several solutions for improving the transfer of technology. One suggestion was to use partnerships to help determine what is working and what is not, based on evidence-based practice. Other suggestions for improving the translation of research into practice included increased advocacy, research, education, and training.

### Redefining the issues

Many members of the workgroup felt that the issues listed were not really health system issues and that important issues that belonged under this topic were missing.

It was noted by several in the group that there was heavy emphasis placed on pharmacological concerns within the six priority issues. The emphasis on pharmacology seemed almost in direct contrast to how many participants defined a health system. They were reminded that the topics had been chosen according to both their importance and their action potential. Many other issues identified in the concept mapping might have fit more closely with the group’s definition of health system issues but may not have been considered very high in action potential.

By consensus, the group identified three overarching themes that they felt needed to be integrated throughout the discussion of health system issues. Those themes included:

- Safety
- Quality
- Disparities

After much discussion, the workgroup members decided to condense several issues and define the three priority issues as listed below.

Key Priorities: Workgroup 7 Health System Issues

1. Medication issues for women
2. Inadequate emphasis on women’s mental health issues in education and training for health care providers
3. Family planning and women with major mental illness

#### Key Priority #1: Medication issues for women

##### Messages

Workgroup members noted that the research shows greater rates of unwanted pregnancies among women with major mental disorders, indicating that their family planning needs are not well-met. The group formulated the following message to address this issue:

Additional evidence-based information is urgently needed concerning the safety and effectiveness of psychotherapeutic medications, including sex and gender and reproductive cycle factors and consideration of nonpharmacological interventions.

This message reflected concerns raised by participants regarding the following issues:

- The lack of information on safety, dosing, and effectiveness of medications during pregnancy and lactation
- The need to include women in clinical trials and understand the pharmacokinetics/pharmacodynamics of drugs
- The need to gain further understanding of the side effects of medication
- The role of hormone therapy in symptomatic perimenopausal women
- The need to define sex and gender broadly – across age, race, ethnicity, and transgender issues

##### Audiences

The primary audience defined by this group for this issue was the research community, including pharmaceutical companies and Federal organizations such as the NIH, the Food and Drug Administration, and the Agency for Healthcare Research and Quality.

##### Formats

The group identified several means and venues for disseminating the message:

- Proclamation
- Request for proposals
- Web-based continuing education for providers
- Advocacy toolkits
- Congress
- Health care providers
- Advocacy groups
- Consumers
- National Health Policy Forum (for Congressional staffers)

##### Cross-cutting cultural concerns

The following issues were identified as cross-cutting cultural concerns:

- Race and ethnic disparities
- Class
- Stigma
- Language barriers
- Belief systems
- Trust
- Stereotypes about legal and immigration status

##### Resources and challenges

The group identified several resources to address this issue, including additional funding, policy changes, and public/private partnerships or collaborations.

In terms of challenges, there were two major areas of concern, including ethical issues and the institutionalization of reporting requirements around race and gender.

#### Key Priority #2: Inadequate emphasis on women’s mental health issues in education and training for health care providers

##### Messages

The group formulated the following message:

Women’s mental health should be incorporated into all levels of health care curricula, including in the knowledge, skills, and attitudes regarding sex and gender differences and issues of race, ethnicity, and culture.

Other issues that participants felt should be included in health care training included:

- Standards of care and best practices
- Knowledge of sex and gender differences in disease manifestations in response to therapy

##### Audiences

The group thought that this message should target the following audiences:

- Health care educators
- Administrators
- Students
- Policymakers
- Health care providers
- Professional organizations
- Case managers

##### Formats

The group identified several means for disseminating the message:

- Communiqués
- Letters to governing bodies of educators
- Press releases for the general public

##### Cross-cutting cultural concerns

Several overarching concerns were raised:

- Racial and ethnic disparities
- Limited English proficiency
- Cultural competence of providers

##### Resources

One resource that this group recommended was the development of a multidisciplinary expert consensus group. The suggestion was made that one of the projects it could undertake would be a multidisciplinary needs assessment.

#### Key Priority #3: Family planning and women with major illness

##### Message

There was consensus among the participants that the term “family planning” was too narrow. It was agreed that “reproductive health” should be added instead for a more comprehensive message. As a result, the following message was proposed by the workgroup:

Discussions about reproductive health and family planning should be incorporated into the care of all women with major mental illness.

##### Audiences

The group proposed several audiences for this message:

- Health care providers
- Students and trainees
- Consumers
- Administrators
- Professional associations

##### Formats

The group identified several formats and venues for disseminating the message:

- Booklets or pamphlets
- PSAs
- Proclamations
- Posters
- Mental health centers
- Drop-in centers
- Correctional facilities
- Professional association meetings
- Advocacy organizations
- Conferences
- Churches

##### Cross-cutting cultural concerns

The following list was identified as incorporating key cultural considerations for effectively disseminating the message:

- Language barriers
- Belief systems regarding reproductive health
- Treatment disparity
- Stigma
- Stereotypes
- Sexual orientation

##### Resources

Workgroup members also proposed several resources to inform and develop this topic:

- Funding sources
- Marketing specialists
- Needs assessments
- Focus groups

Workgroup 7: Health Systems Issues

Facilitators

Duiona Baker, M.P.H., Substance Abuse and Mental Health Services Administration

Laura Miller, M.D., University of Illinois-Chicago

Participants

Ellen Bassuk, M.D., National Center on Family Homelessness

Karen Bower, Esq., Bazelon Center for Mental Health

Rosaly Correa-de-Araujo, M.D., Albert Einstein College of Medicine

Candace Fleming, Ph.D., University of Colorado Health Sciences Center

Howard Goldman M.D., Ph.D., M.P.H., University of Maryland

Mary Harper, Ph.D., R.N., D.Sc., FAAN, LLD, Rosalyn Carter Institute of Family Caregiving, Johnson and Johnson

Catherine Judd, M.S., P.A., University of Texas Medical Branch

Susan Kornstein, M.D., Virginia Commonwealth University

Theanvy Kuoch, M.A., Khmer Health Advocates

Ginger Lerner-Wren, New Freedom Commission

Jaquelyn Resnick, Ph.D., Association for University and College Counseling Centers

Alina Salganicoff, Ph.D., Henry J. Kaiser Family Foundation

Workgroup 8: Protective and Resilience Factors At-A-Glance

Priorities

1. Relationships and social and community supports
2. Knowledge and education
3. Culture, spirituality, traditions, faith, and making meanings

Messages

- Every girl needs at least one supportive, safe, trusting, loving relationship to develop resiliency and positive mental health and wellness.
- Protecting and nurturing your daughter means protecting and nurturing yourself.
- The development of more programs in the arts, sports, music, and such can build self-efficacy and self-esteem as prevention and as a form of healing and recovery.
- Communicate the prevalence, impact, and appropriate response to sexual and physical abuse.
- Sexual and physical abuse traumas exist. Here is the damage they can cause, and here are ways people can protect themselves or recover and heal.
- Create a safe environment by recognizing culture, spirituality and traditions. Respect and validate women’s voices and the meaning that they make out of their life experiences.

Products

PSAs, pamphlets, Web site, radio TV, awareness campaign, research on resilience with resulting materials in plain language, soap opera and talk shows, curriculum development, certification and licensure, criteria for professional competencies, handbooks, literature for adolescents, training curriculum, peer training, ways to acknowledge negative cultural issues (e.g., trauma assessment tool).

## Workgroup 8: Protective and Resilience Factors

The workgroup was asked to pick three priority issues from the list indicated in the following box.

Issues to Prioritize

1. Coping skills for stress and emotional issues
2. Enhancing resilience factors, such as active coping and assertiveness in girls, to prevent emotional problems
3. Lack of knowledge about mental health well-being versus signs and symptoms of mental health problems
4. The relation of physical activity to depression or anxiety treatment
5. Mentoring and positive role modeling

There was considerable discussion surrounding this list, which ultimately the workout group members redefined significantly in order to identify three key priorities for protective and resilience factors.

Numerous overarching issues were raised during the course of this discussion, and they are summarized below:

### Starting young

Much of the general discussion around the question of prioritizing the issues began with an emphasis on the importance of starting young. Participants noted that issues of protective factors and resilience, as well as the risk factors that may undermine them, begin in childhood.

### Relational perspective

Several group members commented on the importance of thinking about resiliency from a relational perspective – for example, the fact that young girls are still socialized to take care of everyone else and not themselves. It was noted that the early literature on resiliency did not take into account the relational approach. More recently there has been a change to adopt this approach and look at results from a contextual perspective to see why some children will do well in one situation while another will not, or why a child will do well in one situation and fail in another.

It also was pointed out that some literature defines resilience differently, following the varied pathways people take to deal with difficulties. Thus, for example, researchers might look at how different people deal with grief, with some finding a way to use it as a growth experience.

### Societal pressures on girls and women

An issue raised by several group members had to do with strong societal pressures on girls and women from the media industry and other social arenas. These pressures change with time, it was noted, and currently reflect the greater sexualization of society, idealized body images, and increased violence.

### Violence, abuse, and trauma

The theme of violence was picked up by several workgroup members, who spoke of personal experiences with the issue of unaddressed childhood trauma resulting from physical and sexual assaults – and the resulting mental health and health risk issues that they lead to later in life. Group members shared stories of family members and others they had known who struggled with the effects of the childhood trauma and had not found the type of treatment or support they needed. For example, one person told of the experience of trying to find help for her daughter, a victim of sexual assault at age 4, in a system that was not equipped to meet her needs – and ultimately failed her. She noted that doctors and teachers were caring but did not have the knowledge or training to help. She expressed her frustration at the way money is spent for conferences and physicians but misses the people who are affected and need help.

Suggestions were made regarding the need to inform providers and others who interact with children better to identify signs of trauma or abuse and to know how to refer victims to appropriate services. The concern was raised that these individuals face the temptation to take the path of least resistance or just to treat the immediate symptoms they see without trying to identify a deeper cause, such as child abuse. One person noted that providers need to be taught to “ask the questions”.

Similarly, several people raised the issue of needing to offer greater supports to parents, including the grown victims of abuse. As one participant pointed out, the average age for posttraumatic stress disorder among girls is 16 years. These girls grow up to have their own children – raising the question of how to build in supports and stop the cycle of victimization.

### Models to build protective factors and resilience

Group members then discussed the importance of protective factors and of creating safe and supportive environments. They spoke of the need for building in supports, such as support groups where people can talk freely, and noted that just one significant relationship can be a protective factor.

There was a call for more models of evidence-based practice and promising practices in all aspects of the mental health system. One person specified that there was a need to change the paradigm from a disease focus to an evidence-based focus.

Participants added that it was important to look at strengths instead of just problems – looking at strengths such as competencies, skills, and abilities. They also noted the protective, strengths-building, self-efficacy developing roles of factors such as sports, physical activity, and good nutrition – though one participant commented that for some children these are not attainable.

Several overarching themes emerged from the group’s discussion:

- To talk about resilience, you must talk about risk.
- The goal is to decrease risk and increase protective factors. Resilience surrounds both.
- Regarding trauma, it is critically important to increase knowledge and education on every level.

### Reframing the priority issues

Group members agreed that the five priority issues that they had been given presented a mismatching combination of formats, with some representing activities and others representing subcategories of broader issues. As a result, participants discussed ways to reframe and repackage the priority issues.

Within this discussion, the concern was raised that other workgroups had been assigned tasks related to risk factors and issues such as trauma and abuse. Thus, the suggestion was made to focus on how to build resiliency with protective factors, with the understanding that this must be done in coordination with the mitigation of risks (which overlaps with other workgroups).

### Identifying protective factors

Participants brainstormed to create an extensive list of protective factors. That list includes safe environment; one or more significant relationships; honoring women’s experiences; nutrition; trust; social supports; community connections; supportive relationships; strength-based competencies, self-efficacy; empowerment; knowledge and education; healthy lifestyles; adequate health care access and quality; ownership and informed choices regarding a woman’s own body; spirituality; cultural values and traditions; respect for diversity, including sexual orientation and women who are not mothers; awareness and acceptance of trauma histories; and integration of mind, body, and spirit.

Four general categories were identified for classifying these different protective factors:

- Relationships and social and community supports
- Strength-based competencies and self-efficacy
- Knowledge, education, and recognition
- Culture, spirituality, and traditions

There was recognition that more research is needed on what factors affect people of different cultures and races.

Following this lengthy discussion, the workgroup defined its own three priority issues, based to some extent on the original list provided, but refined and condensed to reflect the knowledge and concerns of the workgroup participants. Their key priorities are listed in the box below.

Key Priorities: Workgroup 8 Protective Factors and Resilience

1. Relationships and social and community supports
2. Knowledge and education
3. Culture, spirituality, traditions, faith, and making meanings

#### Key Priority #1: Relationships and social and community supports

##### Message

Members of the group commented on the essential importance for girls of having a relationship or bond with someone and that parents often underestimate its importance. They noted that authentic relationships with transparent communication need to start early and continue throughout life. One person added that to start healing, you just need to have some significant relationship with another person. It was noted that this significant relationship does not necessarily have to be with a parent but can be with a person who has their best interests in mind.

Another issue that was raised was how to help parents, particularly mothers, create resilience in their child even if they do not have it themselves.

Based on their discussion, the group members recommended the following messages:

- Every girl needs at least one supportive, safe, trusting, loving, healthy relationship (may or may not be with a biological parent) to develop resiliency and positive mental health and wellness.
- Protecting and nurturing your daughter means protecting and nurturing yourself.

Another area, which came up later in the discussion but was identified as belonging here, focused on looking at or asking what girls are good at and what makes them strong, instead of focusing on pathology. This led to the development of an additional message:

- The development of more programs in the arts, sports, music, and such can build self-efficacy and self-esteem as prevention and as a form of healing and recovery.

##### Audiences

Although the group members recognized that there are numerous potential audiences and could be numerous products for this priority, they tried to narrow the focus. Ultimately, the group decided to focus on two audiences:

- Parents (broadly defined to include caretakers and other parent-like figures)
- Girls

##### Formats

Their proposed formats included:

- PSAs for girls and parents
- Pamphlets
- Research on resilience in girls, including more studies on both what the protective factors are and what builds and destroys resiliency
- Literature for adolescents that reflects lessons from research in plain language

##### Cross-cutting cultural concerns

The group noted that when preparing products for non-English-language audiences, there needs to be not just a linguistic translation but an adaptation that incorporates cultural translation and considerations as well.

Another issue which came up during the discussion was the cultural tradition – for example, among Latinas – to put others before themselves always.

Culture speaks to everyone, gives a message of hope, and helps to make meaning out of life experiences.

##### Dissemination and resources

The following dissemination venues were recommended:

- Schools
- The Internet
- Radio and TV
- Providers’ offices

In terms of resources, the suggestion was made that we need to get youth together (who have not been silenced) to craft the language for girls. Participants noted that attention would have to be paid to ensuring a cross-representation of communities, cultures, and kids who have gone through the good and the bad. The same was recommended for messages targeted to parents.

#### Key Priority #2: Knowledge and education

##### Messages

Although they considered more tailored messages, ultimately members of the workgroup agreed that messages for this topic should be aimed at a broad public audience to try to reduce the stigma surrounding mental health issues.

Two similar suggested messages were proposed, though only the first was included in the PowerPoint presentation for the plenary session. While they overlap, both are presented here to capture the full range of discussion and nuances:

Talk about the prevalence, impact, and appropriate response to sexual and physical abuse across the life span.

Sexual and physical abuse traumas exist. Here is the damage they can cause, and here are the ways people can protect themselves or recover and heal.

##### Audiences

The primary audience identified for this topic was the general public. The secondary ones include providers, educators, and others who interact with girls.

##### Formats

The following formats were proposed:

For the general public:

- PSAs
- Soap operas
- Talk shows
- Peer training (especially for targeted populations)

For professionals:

- Integration of messages into degree training (interdisciplinary), CEUs, licensure by professional associations
- Legislation on training for providers in this area
- Handbooks
- Use of real-life experiences and perspectives from people who have been there and experienced trauma or abuse to help educate providers

##### Cross-cutting cultural concerns

Though it was referred to as a taboo subject, someone noted that in some cultures, incest and domestic violence are acceptable. To address this issue, it is important to use women from within those cultures who want change.

Another issue that was raised under this category was age-appropriate concerns.

#### Key Priority #3: Culture, spirituality, traditions, faith, and making meaning

##### Messages

The group noted that many cultural and spiritual issues were encompassed under the two previous key priority issues. Nonetheless they considered how culture speaks to everyone, gives a message of hope, and helps to make meaning out of life experiences. Similarly, the comment was made that faith helps women and girls to overcome.

Another point was made regarding the need to address the viability of different lifestyles (e.g., gay, lesbian, transgender, bisexual, questioning) without treating them as diagnoses.

A final topic of discussion was the detrimental cultural values in women’s lives. As one person explained, when treating trauma, you always believe the woman; in substance abuse, you never believe the woman because of ingrained ideas that substance users are necessarily liars.

Ultimately, the group proposed the following message:

“Create a safe environment by recognizing culture, spirituality, and traditions. Respect and validate women’s voices and the meaning that they make out of their life experiences.”

##### Audiences

The following audiences were identified for this topic:

- Providers
- Families
- General public

##### Formats

The suggested formats included:

- Criteria for professional development
- Handbooks
- Training curricula
- Ways to acknowledge negative cultural issues (e.g., a newly developed trauma assessment for women to be used as a State standard that addresses these issues)

##### Cross-cutting cultural concerns

Several people commented that it was important to remember that there is a women’s culture that has no cultural/racial boundaries: women have many of the same problems and feel the same way about them.

Nonetheless, there was recognition that providers must be made aware and expected to respect the diverse cultural aspects of people’s lives and what is important to the individual (e.g., many African-American women feel that they must endure and can carry everything on their backs).

Another concern was related to the conflict between professional values and cultural values (e.g., if a girl does not make eye contact, it may be for cultural reasons).

It was also pointed out that the word “resilience” does not exist in Spanish, but there are other cultural values that can promote resilience.

Finally, participants discussed the negative influences of cultural beliefs and norms that may prevent women from seeking help for mental disorders or may pressure them to stay in situations of There was a reminder, too, about the negative aspects of culture and the need to support women who are trying to escape those negative aspects.

Workgroup 8: Protective Factors and Resilience

Facilitators

Sabrina Matoff-Stepp, M.A., HRSA Office of Women’s Health

Sheryl Schrepf, M.S.W., Federation of Families for Children’s Mental Health

Participants

Rene Anderson, Western Massachusetts Training Consortium

Mary Behrens, R.N., M.S.N., FNPC, American Nurses Association

Caroline Clauss-Ehlers, Ph.D., Rutgers University

Norma Finkelstein, Ph.D., Institute for Health and Recovery

Ludy Green, Ph.D., Second Chance Employment Services

Ann Jennings, Ph.D., SAMHSA Center on Women, Violence, and Trauma

Gwendolyn Puryear Keita, PhD, American Psychological Association

Ana Lazu, Latinas Unidos Siempre

Jody Ruskamp-Hatz, M.S.W., National Conference of State Legislatures

Ashley Thornton, Border Children’s Mental Health Collaborative

Antonette Zeiss, Ph.D., Veterans Health Administration