# Participant List

- Hyatt Regency Tech Center
- Denver, CO
- November 30–December 1, 2005

## Participants

- Margarita Alegria, Ph.D.
- Director/Professor of Harvard Medical School Psychiatry
- Center for Multicultural Mental Health Research
- Cambridge Health Alliance, Harvard Medical School
- 120 Beacon Street, Fourth Floor
- Somerville, MA 02143
- Phone: (617) 503-8447
- Fax: (617) 503-8430
- Email: malegria@charesearch.org

- Alan Allery, B.S., M.H.A., M.Ed., M.H.A., Ph.D.
- Director, National Resource Center on
- Native American Aging
- North Dakota Student Health Center for Rural Health
- University of North Dakota School of
- Medicine and Health Science
- P.O. Box 9038
- Grand Forks, ND 58202
- Phone: (701) 777-3859
- Fax: (701) 777-4835
- Email: alan.allery@und.nodak.edu

- Rene Anderson, M.Ed.
- Statewide Parent Advocate Coordinator
- Child & Family Studies
- Florida Mental Health Institute
- 13301 Bruce B. Downs Boulevard
- Tampa, Fl 33612-3899
- Phone: (813) 974-2199
- Fax: (813) 974-7376
- Email: randerso@fmhi.usf.edu

- Thelma Baskin
- 627 West 87th Terrace
- Kansas City, MO 64114
- Phone: (816) 668-3038
- Fax: (816) 349-3344

- Ellen Bassuk, M.D.
- President, National Center on Family
- Homelessness
- Associate Professor of Psychiatry, Harvard
- Medical School
- National Center on Family Homelessness
- 181 Wells Avenue
- Newton, MA 02459
- Phone: (617) 964-3834 Ext. 14
- Fax: (617) 244-1758
- Email: ellen.bassuk@familyhomelessness.org

- Evelyn Becker, Ph.D.
- Clinical Psychologist
- Mental Health Clinic
- Behavioral Health Department
- Indian Health Service
- P.O. Box 649
- Fort Defiance, AZ
- Phone: (928) 729-8503
- Fax: (928) 729-8502
- Email: evelyn.becker@ihs.gov

- Mary Behrens, R.N., M.S.N., F.N.P.-C
- First Vice President
- American Nurses Association
- 5504 East 22nd Street
- Casper, WY 82609
- Phone: (307) 577-5023
- Fax: (307) 234-3283
- Email: mary.behrens@bresnan.net

- Belinda Biscoe, Ph.D.
- Assistant Vice President for University Outreach
- Public and Community Services Administrations
- University of Oklahoma, College of Continuing Education
- 555 East Constitution Avenue, Suite 128
- Norman, OK 73072
- Phone: (405) 325-1711
- Fax: (405) 325-7676
- Email: bpbiscoe@ou.edu

- Andrea Blanch, Ph.D.
- Director
- Center for Women, Violence and Trauma
- 520 Ralph Street
- Sarasota, FL 34242
- Phone: (941) 349-8213
- Fax: (941) 349-8215
- Email: akblanc@aol.com

- Karen A. Bower, Esq.
- Senior Staff Attorney
- Bazelon Center for Mental Health Law
- 1101 15th Street, N.W., Suite 1212
- Washington, DC 20005
- Phone: (202) 467-5730 Ext. 132
- Fax: (202) 223-0409
- Email: karenb@bazelon.org

- Dwana Bush, M.D.
- Family Physician
- The Center for Integrative Health
- 171 Mt. Paran Road, N.E.
- Atlanta, GA 30342
- Phone: (404) 255-5774
- Fax: (404) 255-5994
- Email: dbush@integrativehealth.com

- Angeline Bushy, Ph.D., R.N.
- Professor and Bert Fish Chair School of Nursing
- University of Central Florida
- 1200 Speedway Boulevard
- Daytona Beach, FL 32114
- Phone: (386) 258-6573
- Fax: (386) 506-3998
- Email: abushy@mail.ucf.edu

- Silvia Canetto, Ph.D.
- Professor
- Department of Psychology
- Colorado State University
- Fort Collins, CO 80523
- Phone: (970) 491-5415
- Fax: (970) 491-1032
- Email: scanetto@lamar.colostate.edu

- Sylvia Caras
- 146 Crystal Terrace 5
- Santa Cruz, CA 95060
- Phone: (831) 426-5335
- Fax: (831) 426-5335
- Email: sylvia@peoplewho.org

- Linda Chaudron, M.D., M.S.
- Assistant Professor
- Department of Psychiatry
- University of Rochester School of Medicine
- 300 Crittenden Boulevard, Box Psych
- Rochester, NY 14642
- Phone: (585) 273-2113
- Fax: (585) 276-0307
- Email: linda.chaudron@urmc.rochester.edu

- Elizabeth Clark, Ph.D., A.C.S.W., M.P.H.
- Executive Director
- National Association of Social Workers
- 750 First Street, N.E., Suite 700
- Washington, DC 20002
- Phone: (202) 336-8200
- Fax: (202) 336-8313
- Email: bclark@naswdc.org

- Caroline Clauss-Ehlers, Ph.D.
- Assistant Professor of Counseling Psychology
- Educational Psychology
- Graduate School of Education
- Rutgers University
- 10 Seminary Place
- New Brunswick, NJ 08901
- Phone: (732) 932-7496
- Fax: (732) 932-6829
- Email: csce@rcirutgers.edu

- Susan Cochran, Ph.D., M.S.
- Professor of Epidemiology
- Department of Epidemiology
- UCLA School of Public Health
- University of California, Los Angeles
- Box 951772
- Los Angeles, CA 90095
- Phone: (310) 206-9310
- Fax: (310) 206-6039
- Email: cochran@ucla.edu

- Vickie Coffey, M.S.A.
- Executive Director
- Chicago Metropolitan Battered Women’s Network
- 203 North Wabash Avenue, Suite 2323
- Chicago, IL 60601
- Phone: (312) 750-0730
- Fax: (312) 750-0733
- Email: vcoffey@batteredwomensnetwork.org

- Jerilyn Cohen-Ross, M.A., L.I.C.S.W.
- President and Chief Executive Officer
- Anxiety Disorders Association of America
- 5225 Wisconsin Avenue, N.W., Suite 400
- Washington, DC 20015
- Phone: (202) 363-1010
- Fax: (202) 363-2383
- Email: jerilyn@rosscenter.com

- Lorraine Cole, Ph.D.
- President and Chief Executive Officer
- National Black Women’s Health Imperative
- 600 Pennsylvania Avenue, S.E., Suite 310
- Washington, DC 20003
- Phone: (202) 548-4000
- Fax: (202) 543-9743
- Email: nbwhp@nbwhp.org

- Judith Cook, Ph.D.
- Director, Mental Health Service Research
- Program Professor of Sociology in Psychiatry
- University of Illinois, Chicago
- 104 South Michigan Avenue, Suite 900
- Chicago, IL 60603
- Phone: (312) 422-8180 Ext. 19
- Fax: (312) 422-0740
- Email: cook@ripco.com

- Helen Coons, Ph.D.
- President and Clinical Director
- Women’s Mental Health Association
- 225 South 17th Street, Suite 2701
- Philadelphia, PA 19103
- Phone: (215) 306-2963
- Fax: (610) 667-1985
- Email: hcoons@voicenet.com

- Nereida Correa, M.D.
- Education Core Director
- Bronx Center for Reducing and Eliminating
- Disparities in Health
- Obstetrics, Gynecology and Women’s Health
- Institute of Community and Collaborative Health
- Albert Einstein College of Medicine
- 1300 Morris Park Avenue, Mazur Room 100
- Bronx, NY 10461
- Phone: (718) 430-2753
- Fax: (718) 430-3729
- Email: ncorrea@montefiore.org

- Rosaly Correa-de-Araujo, M.D., M.Sc., Ph.D.
- Director of Women’s Health and Gender Based Research
- Agency for Healthcare and Research and Quality
- U.S. Department of Health and Human Services
- 540 Gaither Road
- Rockville, MD 20850
- Phone: (301) 427-1550
- Fax: (301) 427-1562
- Email: ncorrea@ahrq.gov

- Kathleen DeBold, B.S.
- Executive Director
- The Mautner Project
- 1707 L Street, N.W., Suite 230
- Washington, DC 20036
- Phone: (202) 332-5536
- Fax: (202) 332-0662
- Email: kdebold@mautnerproject.org

- Rani Desai, Ph.D., M.P.H.
- Section Chair
- Mental Health Section
- American Public Health Association
- NEPEC/182, VA CT Health Care System
- 950 Campbell Avenue
- West Haven, CT 06546
- Phone: (203) 937-3850
- Fax: (203) 937-3463
- Email: rani.desai@yale.edu

- Deborah Donaldson
- Director, Human Services Chair
- Sedgwick County NACBHD
- 635 North Main
- Wichita, KS 67203
- Phone: (316) 660-7670
- Fax: (316) 383-7925
- Email: ddonalds@sedgwick.gov

- Charlene Doria-Ortiz
- Executive Director
- Center for Health Policy Development, Inc.
- 6989 Alamo Downs Parkway
- San Antonio, TX 78238
- Phone: (210) 520-8020
- Fax: (210) 520-9522
- Email: chpd@chpdonline.org

- Norma Finkelstein, Ph.D.
- Executive Director
- Institute for Health and Recovery
- 349 Broadway
- Cambridge, MA 02139
- Phone: (617) 661-3991
- Fax: (617) 661-7277
- Email: normafinkelstein@healthrecovery.org

- Rachel Fleissner, M.D.
- Child Psychiatrist, Medical Director
- Associate Professor
- American Academy Child and Adolescent Psychiatry
- Prairie St. Johns
- University of North Fargo
- 510 Fourth Street South
- Fargo, ND 58103
- Phone: (701) 476-7860
- Fax: (701) 280-5795
- Email: rfleissner@prairie-stjohns.com

- Candace Fleming, Ph.D.
- Associate Professor
- Psychiatry, F800
- American Indian and Alaska Native Programs
- University of Colorado Health Sciences Center
- P.O. Box 6508
- Aurora, CO 80045-0508
- Phone: (303) 724-1471
- Fax: (303) 724-1474
- Email: candace.fleming@uchsc.edu

- Linda Frisman, Ph.D.
- Director of Research
- Department of Mental Health and Addiction Services Research
- University of Connecticut
- 410 Capitol Avenue, MS #14 RSD
- Hartford, CT 06106
- Phone: (860) 418-6788
- Fax: (860) 418-6692
- Email: linda.frisman@uconn.edu

- Patricio Garcia
- Lieutenant
- Office of the Surgeon General
- 5600 Fishers Lane, Room 18-66
- Rockville, MD 20857
- Mary Gee, B.A.
- Evaluator/FAC Liaison
- Eating Disorders Coalition for Research,
- Policy and Action
- Davis Y. Ja and Associates, Inc.
- 362 Victoria Street
- San Francisco, CA 94132
- Phone: (415) 585-2773
- Fax: (415) 239-4511
- Email: mgee@isomers.com

- Joan Gillece, Ph.D.
- Program Manager of Seclusion and Restraint
- Division of Specific Populations, Mental
- Hygiene Administration
- National Technical Assistance Center
- National Association of State Mental Health Program Directors
- 66 Canal Plaza, Suite 302
- Alexandria, VA 22314
- Phone: (703) 739-9333
- Fax: (703) 548-9517
- Email: joan.gillece@nasmhpd.org

- Howard Goldman, M.D., M.P.H., Ph.D.
- Professor
- Department of Psychiatry
- University of Maryland
- 10600 Trotters Trail
- Potomac, MD 20854
- Phone: (301) 983-1671
- Email: hh.goldman@verizon.net

- Susan Gorin, C.A.E.
- Executive Director
- National Association of School Psychologists
- 4340 East West Highway, Suite 402
- Bethesda, MD 20814
- Phone: (301) 347-1640
- Fax: (301) 657-4323
- Email: sgorin@naspweb.org

- Ludy Green, Ph.D.
- President and Founder
- Second Chance Employment Services
- 818 18th Street, N.W., Suite 420
- Washington, DC 20006
- Phone: (202) 486-7428
- Fax: (202) 331-7428
- Email: ludygreen@aol.com

- Melva Green, M.D.
- American Psychiatric Association
- 1000 Wilson Boulevard, Suite 1825
- Arlington, VA 22209-3901
- Phyllis Greenberger, M.S.W.
- President and Chief Executive Officer
- Society for Women’s Health Research
- 1025 Connecticut Avenue, N.W., Suite 701
- Washington, DC 20036
- Phone: (202) 223-8224
- Fax: (202) 833-3472

- Gloria Grijalva-Gonzales
- Certified Substance Abuse Counselor
- Behavioral Health Services
- Substance Abuse Services
- San Joaquin County Health Care Services
- P.O. Box 690491
- Stockton, CA 95269
- Phone: (209) 518-0670
- Fax: (209) 468-7032
- Email: gloria6587@sbcglobal.com

- Yoon Han, M.Ed., M.S.W.
- Project Director
- Behavioral Health
- Asian Counseling and Referral Service
- 720 Eighth Avenue, South, Suite 200
- Seattle, WA 98104
- Phone: (206) 695-7591
- Fax: (206) 965-7606
- Email: yoonjooh@acrs.org

- Maxine Harris, Ph.D.
- Chief Executive Officer for Clinical Affairs and Co-Founder
- Community Connections
- 801 Pennsylvania Avenue, S.E., Suite 201
- Washington, DC 20003
- Phone: (202) 546-1512
- Fax: (202) 544-5365
- Email: mharris@ncemi.org

- Pablo Hernandez, M.D.
- Superintendent
- Wyoming Department of Health
- Wyoming State Hospital
- P.O. Box 177, 831 Highway 150 South
- Evanston, WY 82931-0177
- Phone: (307) 789-3464
- Fax: (307) 789-5277
- Email: pherna@state.wy.us

- Larke Huang, Ph.D.
- Managing Research Scientist
- American Institutes for Research
- 1000 Thomas Jefferson Street, N.W.
- Washington, DC 20007
- Phone: (202) 403-5180
- Fax: (202) 403-5007
- Email: lhuang@air.org

- Gail Hutchings, M.P.A.
- Chief of Staff
- Behavioral Health Policy Collaborative, LLC
- Substance Abuse and Mental Health Services Administration
- U.S. Department of Health and Human Services
- 4923 Waple Lane
- Alexandria, VA 22304
- Phone: (240) 276-2000
- Fax: (240) 276-2010
- Email: gailhutch@aol.com

- Barbara Hylard
- Director of Constituency Relations
- Depression and Bipolar Support Alliance
- 730 North Franklin Street, Suite 501
- Chicago, IL 60610
- Phone: (800) 826-3632
- Fax: (312) 642-7243
- Email: bhylard@dbsalliance.org

- D. J. Ida, Ph.D.
- Executive Director
- National Asian American Pacific Islander
- Mental Health Association
- 1215 19th Street, Suite A
- Denver, CO 80202
- Phone: (303) 298-7910
- Fax: (303) 298-8081
- Email: djida@naapimha.org

- Carmen Inoa-Vazquez, Ph.D.
- Director, Institute for Multicultural Health Department of Psychiatry
- Bellevue Hospital Center
- 104 East 40th Street, Suite 607
- New York, NY 10016
- Phone: (212) 689-2528
- Fax: (413) 375-4393
- Email: drvazquez@drcarmenvazquez.com

- Ann Jennings, Ph.D.
- Trauma Systems Consultant
- Center on Women, Violence and Trauma
- Substance Abuse and Mental Health
- Services Administration
- 21 Ocean Street
- Rockland, ME 04841
- Phone: (207) 712-3516
- Email: afj@gwi.net

- Catherine Judd, M.S., P.A.
- Clinical Assistant Professor
- Physician Assistant Program
- South Western Allied Health Sciences
- University of Texas Medical Branch
- 120 Shadybrook Drive
- DeSoto, TX 75115
- Phone: (972) 223-7321
- Email: cjudd1@hotmail.com

- Nadine Kaslow, Ph.D.
- Professor and Chief Psychologist
- Department of Psychiatry and Behavioral Sciences
- Grady Health System
- Emory University School of Medicine
- 80 Jesse Hill Jr. Drive, S.E.
- Atlanta, GA 30303
- Phone: (404) 616-4757
- Fax: (404) 616-2898
- Email: nkaslow@emory.edu

- Luella Klein, M.D.
- Vice President
- Division of Women’s Health Issues
- American College of Obstetricians and Gynecologists
- 409 12th Street, S.W.
- Washington, DC 20024
- Phone: (202) 863-2434
- Fax: (202) 484-3917
- Email: lklein@acog.org

- Susan Kornstein, M.D.
- Professor of Psychiatry and Obstetrics/Gynecology
- Department of Psychiatry Virginia Commonwealth University
- 3805 Cutshaw Avenue, Suite 504
- Richmond, VA 23230
- Phone: (804) 828-5647
- Fax: (804) 828-5644
- Email: skornste@mail2.vcu.edu

- Theanvy Kuoch, M.A.
- Executive Director
- Kmer Health Advocates
- 29 Shadow Lane
- West Hartford, CT 06110
- Phone: (860) 561-3345
- Email: MFS47@aol.com

- Denise Laine, Ph.D.
- Manager, Past President of American Academy of Nurse Practitioners
- Employee Health and Infectious Control
- National Jewish Medical and Research Center
- American Academy of Nurse Practitioners
- 1400 Jackson Street, Southside G-119
- Denver, CO 80206-2761
- Phone: (303) 348-1604
- Fax: (303) 270-2232
- Email: lained@ojc.org

- Jean Lau Chin, Ed.D., A.B.P.P.
- Dean
- California School of Professional Psychology
- Alliant International University
- One Beach Street
- San Francisco, CA 94133
- Phone: (415) 955-2048
- Fax: (415) 955-2063
- Email: jchin@alliant.edu

- Ana Lazu
- Executive Director
- Latinas Unidos Siempre
- 59 Broadway
- Norwich, CT 06360
- Phone: (860) 887-4844
- Email: analazu@aol.com

- Carmen Lee
- Executive Director
- Stamp Out Stigma
- 1572 Winding Way, Suite A
- Belmont, CA 94002
- Phone: (650) 592-2345
- Email: carmensos@aol.com

- Ginger Lerner-Wren
- New Freedom Commission
- 17th Judicial Circuit, Broward County Florida
- 201 S.E. Sixth Street
- Ft. Lauderdale, FL 33301
- Phone: (954) 831-7240
- Fax: (954) 765-4848
- Email: carriola@17th.flcourts.org

- Richard M. Lerro, M.L.A.
- Executive Director
- Eating Disorders Coalition
- 611 Pennsylvania Avenue, S.E. #423
- Washington, DC 20003
- Phone: (202) 542-9570
- Fax: (202) 542-9570
- Email: mlerro@eatingdisorderscoalition.org

- Ruta Mazelis
- Editor, Cutting Edge Newsletter
- Sidran Institute
- 6196 Vo Ash Drive, S.W.
- Carrollton, OH 44615
- Phone: (330) 627-5411
- Email: rutamaze@eohio.net

- Carolyn Mazure, Ph.D.
- Director, Women’s Health Research at Yale
- Associate Dean for Faculty Affairs
- Professor of Psychology
- Yale University School of Medicine
- P.O. Box 208091
- New Haven, CT 06520
- Phone: (203) 764-6600
- Fax: (203) 764-6609
- Email: carolyn.mazure@yale.edu

- Jacki McKinney, M.S.W.
- Director
- Trauma Knowledge Utilization Project
- Center on Women, Violence and Trauma
- 5124 New Hall Street
- Philadelphia, PA 19144
- Phone: (215) 844-2540

- Dennis Mohatt
- Senior Program Director
- Western Interstate Commission on Higher Education
- 3035 Center Green Drive
- Boulder, CO 80301
- Phone: (303) 541-0256
- Fax: (303) 541-0291
- Email: dmohatt@wiche.edu

- Oscar Morgan, M.A.
- Senior Vice President
- Policy and Services
- National Mental Health Association
- 2001 North Beauregard Street, 12th Floor
- Alexandria, VA 22311
- Phone: (703) 838-7523
- Fax: (703) 684-5968
- Email: omorgan@nmha.org

- Pamela Mulder, Ph.D.
- Associate Professor
- Department of Psychology
- Marshall University
- One John Marshall Drive
- Huntington, WV 25755
- Phone: (304) 696-2770
- Fax: (304) 696-2784
- Email: mulder@marshall.edu

- Frances Murphy, M.D., M.P.H.
- Director
- Deputy Under Secretary for Health Policy Coordination
- Veterans Health Administration
- U.S. Department of Veterans Affairs
- 810 Vermont Avenue, N.W., Suite 10-H
- Washington, DC 20420
- Phone: (202) 565-6363
- Fax: (202) 565-4207
- Email: frances.murphy@hq.med.va.gov

- Lisa Najavits, Ph.D.
- Associate Professor of Psychology
- Department of Psychiatry
- Women’s Health Sciences Division
- Veterans Affairs Boston Healthcare System
- 150 South Huntington Avenue
- Jamaica Plains, MA 02130
- Phone: (617) 364-2780
- Email: lisa.najavits@med.va.gov

- Joanne Nicholson, Ph.D.
- Associate Professor of Psychiatry and Family Medicine
- Department of Psychiatry
- Center for Mental Health Services Research
- University of Massachusetts Medical School
- 55 Lake Avenue North
- Worcester, MA 01655
- Phone: (508) 856-8712
- Fax: (508) 856-8700
- Email: joanne.nicholson@umassmed.edu

- Susan Nolen-Hoeksema, Ph.D.
- Professor
- Psychology Department
- Yale University
- P.O. Box 208205, Two Hillhouse Avenue
- New Haven, CT 06520
- Phone: (203) 432-0699
- Fax: (203) 432-7172
- Email: susan.nolen-hoeksemia@yale.edu

- Eileen Ouellette, M.D., J.D., F.A.A.P.
- American Academy of Pediatrics
- 141 Northwest Point Boulevard
- Elk Grove, IL 60007
- Phone: (508) 228-0035
- Email: eouellette@aap.org

- Jon Perez, Ph.D.
- Director
- Division of Behavioral Health
- Indian Health Service
- 12300 Twinbrook Parkway
- Rockville, MD 20852
- Phone: (240) 506-7492
- Email: jperez@hqe.ihs.gov

- Karen Peterson, M.D.
- Psychiatrist
- Psychiatry Department
- Center for the Study of Traumatic Stress
- Uniformed Services University of the Health Sciences
- 10220 Grant Avenue
- Silver Spring, MD 20910
- Phone: (301) 588-0954
- Fax: (301) 295-2470
- Email: kpeterson@usuhs.mil

- Rick Peterson, Ph.D.
- President
- Texas A&M University
- National Association of Rural Mental Health
- 2251 TAMU
- College Station, TX 77843
- Phone: (979) 845-1877
- Fax: (979) 845-6496
- Email: rlpeterson@ag.tamu.edu

- Laura Prescott, B.A.
- President and Founder
- Sister Witness International, Inc.
- 315 Vermont Street
- West Roxbury, MA 02132
- Phone: (617) 469-3233
- Fax: (309) 414-9467
- Email: lpleiades@aol.com

- Gwendolyn Puryear Keita, Ph.D.
- Associate Executive Director
- Women’s Programs Office
- Public Interest Doctorate
- American Psychological Association
- 750 First Street, N.E.
- Washington, DC 20002
- Phone: (202) 336-6044
- Fax: (202) 336-6117
- Email: gkeita@apa.org

- Shirley Repta, Ph.D., M.B.A., A.P.R.N., B.C.
- Executive Director
- American Psychiatric Nurses Association
- 1555 Wilson Boulevard, Suite 602
- Arlington, VA 22209
- Phone: (703) 243-2442
- Fax: (703) 243-3390
- Email: srepta@apna.org

- Jaquelyn Resnick, Ph.D.
- President
- Association for University and College
- Counseling Center Directors
- P.O. Box 114100
- Gainesville, FL 32611
- Phone: (352) 392-1575
- Fax: (352) 392-8453
- Email: resnick@counsel.ufl.edu

- Paulette Running Wolf, Ph.D.
- Executive Director
- First Nations Behavioral Health Association
- Box 345
- Babb, MT 59411
- Phone: (406) 732-4240
- Fax: (406) 732-9960
- Email: pauletterunningwolf@hotmail.com

- Jody Ruskamp-Hatz, M.S.W.
- Policy Specialist
- Health Program
- National Conference of State Legislatures
- 7700 East First Place
- Denver, CO 80230
- Phone: (303) 856-1521
- Fax: (303) 364-7800
- Email: jody.hatz@ncsl.org

- Alina Salganicoff, Ph.D.
- Vice President
- Women’s Health Policy
- Henry J. Kaiser Family Foundation
- 2400 Sand Hill Road
- Menlo Park, CA 94702
- Phone: (650) 854-9400
- Fax: (650) 854-4800
- Email: alinas@kff.org

- Maria Sanchez
- National Latino Behavioral Health Association
- P.O. Box 387
- Berthoud, CO 80513
- Phone: (303) 932-1007
- Fax: (720) 981-1384
- Email: maria.sanchez@nlbha.org

- Catherine Shisslak, Ph.D.
- Professor
- Family and Community Medicine
- University of Arizona, College of Medicine
- 1533 East Mabel Street
- Tucson, AZ 85718
- Phone: (520) 904-4252
- Fax: (520) 792-3756
- Email: cms@u.arizona.edu

- Adrienne Smith, Ph.D.
- Public Health Advisor
- Office on Women’s Health
- U.S. Department of Health and Human Services
- 200 Independence Avenue, S.W., Room
- 733E
- Washington, DC 20201
- Phone: (202) 690-5884
- Fax: (202) 690-7172
- Email: asmith@osophs.dhhs.gov

- Nancy C. Speck, Ph.D.
- Mental Health Consultant
- P.O. Box 62247
- Houston, TX 77205
- Phone: (936) 554-0562
- Email: nspeck@earthlink.net

- Lincoln Stanley, M.A.
- Government Affairs Manager
- Legal and Governmental Affairs
- American Association for Marriage and Family Therapy
- 112 South Alfred Street
- Alexandria, VA 22314
- Phone: (703) 253-0469
- Fax: (703) 253-0506
- Email: lstanley@aamft.org

- Sharon Sweede, M.D.
- Past Chair, Commission on Public Health
- American Academy of Family Physicians
- 20 Hanby Drive
- Asheville, NC 28803
- Phone: (828) 298-7911 Ext. 14188
- Fax: (828) 299-2550
- Email: sharon.sweede@med.va.gov

- David Takeuchi, Ph.D.
- Professor
- School of Social Work
- University of Washington
- 4101 15th Avenue, N.E.
- Seattle, WA 98105
- Phone: (206) 543-5133
- Fax: (206) 221-3910
- Email: dt5@u.washington.edu

- Ashley Thornton
- Youth Coordinator
- Border Children’s Mental Health
- Collaborative
- 7104 Luz de Espejo
- El Paso, TX 79912
- Phone: (915) 833-2890
- Email: angelashley04@hotmail.com

- Carole Warshaw, M.D.
- Executive Director
- Domestic Violence and Mental Health
- Policy Initiative
- National Training and Technical Assistance
- Center on Domestic Violence, Trauma and Mental Health
- 75 East Wacker Drive, Suite 520
- Chicago, IL 60601
- Phone: (312) 726-7020
- Fax: (312) 726-7022
- Email: clwarshaw@aol.com

- Katherine Wisner, M.D., M.S.
- Professor of Psychiatry
- Department of Psychiatry
- Western Psychiatric Institute and Clinic
- University of Pittsburgh Medical Center
- 3811 O’Hara Street
- Pittsburg, PA 15213
- Phone: (412) 246-6564
- Fax: (412) 246-6960
- Email: wisnerk1@upmc.edu

- Barbara Yee, Ph.D.
- Professor and Chair
- Family and Consumer Sciences
- College of Tropical Agriculture and Human Resources
- University of Hawaii, Manoa
- 2515 Campus Road, Miller Hall 110
- Honolulu, HI 96822
- Phone: (808) 956-8105
- Fax: (808) 956-2419
- Email: yeebarba@hawaii.edu

- Antonette Zeiss, Ph.D.
- Deputy Chief Consultant
- Office of Mental Health Services
- Veterans Health Administration
- U.S. Department of Veterans Affairs
- 810 Vermont Avenue, N.W., Suite 116
- Washington, DC 20420
- Phone: (202) 273-7322
- Fax: (202) 273-9069
- Email: antonette.zeiss2@va.gov

### Presenters

- Rene Andersen, M.Ed.
- Center on Women, Violence, and Trauma
- Public and Community Services Division
- Western Massachusetts Training Consortium
- 187 High Street, Suite 204
- Holyoke, MA 01040
- Phone: (413) 536-2401 Ext. 3006
- Email: randersen@wmtcinfo.org

- Cheryl Bowers-Stephens, M.D., M.B.A.
- Assistant Secretary
- Office of Mental Health
- Louisiana Department of Health and Hospitals
- 1201 Capital Access Road, Bin# 12
- Baton Rouge, LA 70821
- Phone: (225) 342-2540
- Fax: (225) 342-1984
- Email: cstephen@dhh.la.gov

- Richard H. Carmona, M.D., M.P.H., FACS
- U.S. Surgeon General
- Office of the Surgeon General
- 5600 Fishers Lane, Room 18-66
- Rockville, MD 20857
- Wanda K. Jones, Dr.P.H.
- Deputy Assistant Secretary for Health
- Office on Women’s Health
- U.S. Department of Health and Human Services
- 200 Independence Avenue, S.W.,
- Room 712E
- Washington, DC 20201
- Phone: (202) 260-4432
- Fax: (202) 401-4005
- Email: wjones@osophs.dhhs.gov

- Kenneth P. Moritsugu, M.D., M.P.H.
- Rear Admiral
- Deputy Surgeon General
- Office of the Surgeon General
- 5600 Fishers Lane, Room 18-66
- Rockville, MD 20857

- Richard K. Nakamura, Ph.D.
- Deputy Director
- National Institute of Mental Health
- National Institutes of Health
- 6001 Executive Boulevard, Room
- 8235/MSC 9669
- Rockville, MD 20852-9669
- Phone: (301) 443-3675
- Fax: (301) 443-2578
- Email: r.nakamura@nih.gov

- A. Kathryn Power, M.Ed.
- Director, Center for Mental Health Services
- Substance Abuse and Mental Health
- Services Administration
- U.S. Department of Health and Human Services
- One Choke Cherry Road, Room 6-1055
- Rockville, MD 20852
- Phone: (240) 276-1310
- Fax: (240) 276-1320
- Email: kathryn.power@samhsa.hhs.gov

### Facilitators

- Rene Andersen, M.Ed.
- Center on Women, Violence, and Trauma
- Public and Community Services Division
- Western Massachusetts Training Consortium
- 187 High Street, Suite 204
- Holyoke, MA 01040
- Phone: (413) 536-2401 Ext. 3006
- Email: randersen@wmtcinfo.org

- Duiona Baker, M.P.H.
- Associate Administrator
- Substance Abuse and Mental Health
- Services Administration
- U.S. Department of Health and Human Services
- One Choke Cherry Road, Room 8-1009
- Rockville, MD 20857
- Phone: (240) 276-2244
- Fax: (240) 276-1076
- Email: duiona.baker@samhsa.hhs.gov

- Kinike Bermudez-Walker
- Consumer Program Director
- National Asian American Pacific Islander
- Mental Health Association
- 2365 West Buckingham Road, #1094
- Garland, TX 75042
- Phone: (214) 597-8755
- Fax: (214) 954-0611
- Email: kinikebermudez@yahoo.com

- Teresa Chapa, Ph.D., M.P.A.
- Director
- Division of Policy and Data
- Office of Minority Health
- U.S. Department of Health and Human Services
- 1101 Wootton Parkway, Suite 600
- Rockville, MD 20852
- Phone: (240) 453-6168
- Email: tchapa@osophs.dhhs.gov

- Ellen Frank, Ph.D.
- Professor of Psychiatry and Psychology
- Department of Psychiatry
- Western Psychiatric Institute and Clinic
- University of Pittsburgh Medical Center
- 3811 O’Hara Street
- Pittsburgh, PA 15213
- Phone: (412) 246-5550
- Fax: (412) 246-5530
- Email: franke@upmc.edu

- Sabrina Matoff-Stepp, M.A.
- Director
- Office of Women’s Health
- Health Resources and Services
- Administration
- U.S. Department of Health and Human Services
- 5600 Fishers Lane, Room 18A-44
- Rockville, MD 20857
- Phone: (301) 443-8695
- Fax: (301) 443-8587
- Email: smatoff-stepp@hrsa.gov

- Vickie Mays, Ph.D., M.S.P.H.
- Professor of Psychology and Health Services
- Institute for Social Science Research
- University of California, Los Angeles
- Box 951484, 4250 PPB
- Los Angeles, CA 90095-484
- Phone: (310) 206-5159
- Fax: (310) 206-5895
- Email: mays@ucla.edu

- Laura Miller, M.D.
- Director
- Department of Psychiatry
- Women’s Mental Health
- University of Illinois, Chicago
- 912 South Wood Street, M/C 913
- Chicago, IL 60612
- Phone: (312) 996-5090
- Fax: (312) 413-4265
- Email: ljm@psych.uic.edu

- A. Kathryn Power, M.Ed.
- Director, Center for Mental Health Services
- Substance Abuse and Mental Health
- Services Administration
- U.S. Department of Health and Human Services
- One Choke Cherry Road, Room 6-1055
- Rockville, MD 20852
- Phone: (240) 276-1310
- Fax: (240) 276-1320
- Email: kathryn.power@samhsa.hhs.gov

- Catherine Roca, M.D.
- Chief, Women’s Program
- Office for Special Populations
- National Institute of Mental Health
- U.S. Department of Health and Human Services
- 6001 Executive Boulevard, Suite 8125
- Rockville, MD 20852
- Phone: (301) 443-3488
- Fax: (301) 443-8552
- Email: croca@mail.nih.gov

- Susan E. Salasin
- Director, Women and Violence Program
- Director, Mental Health and Criminal Justice Program
- Center for Mental Health Services
- Substance Abuse and Mental Health
- Services Administration
- U.S. Department of Health and Human Services
- One Choke Cherry Road, Room 6-1021
- Rockville, MD 20850
- Phone: (240) 276-1908
- Fax: (240) 276-1960
- Email: susan.salasin@samhsa.hhs.gov

- Sheryl Schrepf, M.S.W.
- Regional Technical Assistance Coordinator
- Federation of Families for Children’s Mental Health
- 2708 West Bluff Road
- Lincoln, NE 68524
- Phone: (402) 470-3785
- Email: sschrepf@ffcmh.org

- R. Dale Walker, M.D., Ph.D.
- Psychiatrist
- Oregon Health and Science University
- 3181 S.W. Sam Jackson Park Road
- Mail Code: GH 151
- Portland, OR 97239
- Phone: (503) 494-3703
- Fax: (503) 494-2907
- Email: onesky@ohsu.edu

- Cora Wetherington, Ph.D.
- Women and Gender Research Coordinator
- Sex and Gender Programs
- National Institute on Drug Abuse
- 6001 Executive Boulevard
- Room 4282, MSC 9555
- Rockville, MD 20882
- Phone: (301) 443-1263
- Fax: (301) 594-6043
- Email: wetherington@nih.gov

- Jane Wilson, M.S.
- Acting Regional Health Administrator
- Office of Public Health and Sciences
- U.S. Department of Health and Human Services
- 1961 Stout Street, Room 498
- Denver, CO 80294-3538
- Phone: (303) 844-7859
- Fax: (303) 844-2019
- Email: jwilson@osophs.dhhs.gov

- Kimberly Yonkers, M.D.
- Associate Professor
- Psychiatry and Epidemiology and Public Health
- Yale University School of Medicine
- 142 Temple Street, Suite 301
- New Haven, CT 06510
- Phone: (203) 764-6621
- Fax: (203) 764-6766
- Email: kimberly.yonkers@yale.edu

### Writers

- Amy Brown
- Policy Associate
- Evaluation and Research Methods
- Health Systems Research, Inc.
- 1200 18th Street, N.W., Suite 700
- Washington, DC 20036
- Phone: (202) 828-5100
- Fax: (202) 828-9469
- Email: abrown@hsrnet.com

- Jason Fizell
- Manager, Proposal Development
- Communications Department
- Health Systems Research, Inc.
- 1200 18th Street, N.W., Suite 700
- Washington, DC 20036
- Phone: (202) 828-5100
- Fax: (202) 728-9469
- Email: jfizell@hsrnet.com

- Stacy Gleason, M.P.H.
- Policy Associate
- Evaluation and Research Methods
- Health Systems Research, Inc.
- 1200 18th Street, N.W., Suite 700,
- Washington, DC 20036
- Phone: (202) 828-5100
- Fax: (202) 728-9469
- Email: sgleason@hsrnet.com

- Stephanie Hauser
- Research Analyst
- Behavioral Health Promotion. Treatment and Recovery
- Health Systems Research, Inc.
- 1200 18th Street, N.W., Suite 700
- Washington, DC 20036
- Phone: (202) 828-5100
- Fax: (202) 728-9469
- Email: shauser@hsrnet.com

- Kathryn Hudson, M.P.A.
- Senior Policy Associate
- Behavioral Health Promotion. Treatment and Recovery
- Health Systems Research, Inc.
- 1200 18th Street, N.W., Suite 700
- Washington, DC 20036
- Phone: (202) 828-5100
- Fax: (202) 728-9469
- Email: khudson@hsrnet.com

- Matthew McCoy
- Research Analyst
- Evaluation and Research Methods
- Health Systems Research, Inc.
- 1200 18th Street, N.W., Suite 700
- Washington, DC 20036
- Phone: (202) 828-5100
- Fax: (202) 728-9469
- Email: mmcoy@hsrnet.com

- Gretchen Noonan, M.S.
- Policy Associate
- Health Policy
- Health Systems Research, Inc.
- 1200 18th Street, N.W., Suite 700
- Washington, DC 20036
- Phone: (202) 828-5100
- Fax: (202) 728-9469
- Email: gnoonan@hsrnet.com

- Laura Sternesky, M.P.A.
- Policy Associate
- Evaluation and Research Methods
- Health Systems Research, Inc.
- 1200 18th Street, N.W., Suite 700
- Washington, DC 20036
- Phone: (202) 828-5100
- Fax: (202) 728-9469
- Email: lsternesky@hsrnet.com

### HSR Staff

- Ann Elderkin, P.A.
- Project Director
- Health Policy
- Health Systems Research, Inc.
- 1200 18th Street, N.W., Suite 700
- Washington, DC 20036
- Phone: (202) 828-5100
- Fax: (202) 728-9469
- Email: aelderkin@hsrnet.com

- Valerie Gwinner, M.P.P., M.A.
- Director
- Communications Department
- Health Systems Research, Inc.
- 1200 18th Street, N.W., Suite 700
- Washington, DC 20036
- Phone: (202) 828-5100
- Fax: (202) 728-9469
- Email: vgwinner@hsrnet.com

- Jamie Hart, Ph.D., M.P.H.
- Director
- Intercultural Health
- Health Systems Research, Inc.
- 1200 18th Street, N.W., Suite 700
- Washington, DC 20036
- Phone: (202) 828-5100
- Fax: (202) 728-9469
- Email: jhart@hsrnet.com

- Joy King
- Senior Meetings Manager
- Conference and Project Management
- Health Systems Research, Inc.
- 1200 18th Street, N.W., Suite 700
- Washington, DC 20036
- Phone: (202) 828-5100
- Fax: (202) 728-9469
- Email: jking@hsrnet.com

- Tamar Shealy
- Meetings Manager
- Conference and Project Management
- Health Systems Research, Inc.
- 1200 18th Street, N.W., Suite 700
- Washington, DC 20036
- Phone: (202) 828-5100
- Fax: (202) 728-9469
- Email: tshealy@hsrnet.com