# References

1 Kerchner K, Fleischer A, Yosipovitch G. Lower extremity lymphedema update: pathophysiology, diagnosis, and treatment guidelines. [Review] [34 refs]. J Am Acad Dermatol. 2008;59(2):324-31. [pmid: 18513827].
2 Warren AG, Brorson H, Borud LJ, et al. Lymphedema: a comprehensive review. [Review] [104 refs]. Ann Plast Surg. 2007;59(4):464-72. [pmid: 17901744].
3 Simonian SJ, Morgan CL, Tretbar LL, et al. Differential Diagnosis of Lymphedema. Lymphedema: Diagnosis and Treatment. London. Springer-Verlag London Limited. 2. 2008:12-20.
4 International Society of Lymphology. The diagnosis and treatment of peripheral lymphedema. 2009 Concensus Document of the International Society of Lymphology. Lymphology. 2009;42(2):51-60. [pmid: 19725269].
5 Levenback C. Update on sentinel lymph node biopsy in gynecologic cancers. Gynecol Oncol. 2008;111(2 Suppl):S42-S43. [pmid: 18804266].
6 McLaughlin SA, Wright MJ, Morris KT, et al. Prevalence of lymphedema in women with breast cancer 5 years after sentinel lymph node biopsy or axillary dissection: objective measurements. J Clin Oncol. 2008;26(32):5213-9. [pmid: 18838709].
7 Gill G. Sentinel-lymph-node-based management or routine axillary clearance? One-year outcomes of sentinel node biopsy versus axillary clearance (SNAC): a randomized controlled surgical trial. Ann Surg Oncol. 2009;16(2):266-75. [pmid: 19050973].
8 Florez-Garcia MT, Valverde-Carrillo MD. Effectiveness of nonpharmacological interventions in the management of lymphedema postmastectomy. Rehabilitacion. 2007;41(3):126-34.
9 Kligman L, Wong RK, Johnston M, et al. The treatment of lymphedema related to breast cancer: a systematic review and evidence summary. [Review] [30 refs]. Support Care Cancer. 2004;12(6):421-31. [pmid: 15095073].
10 Moseley AL, Carati CJ, Piller NB. A systematic review of common conservative therapies for arm lymphoedema secondary to breast cancer treatment. [Review] [61 refs]. Ann Oncol. 2007;18(4):639-46. [pmid: 17018707].
11 Badger C, Preston N, Seers K, et al. Physical therapies for reducing and controlling lymphoedema of the limbs. [Review] [21 refs]. Cochrane Database Syst Rev. 2004;(4):CD003141. [pmid: 15495042].
12 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3(25). [doi: 10.1186/1471-2288-3-25]. [pmid: 14606960].
13 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: Is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. ISI:A1996UA39800001. [pmid: 8721797].
14 Oremus M, Wolfson C, Perrault A, et al. Interrater reliability of the modified Jadad quality scale for systematic reviews of Alzheimer's disease drug trials. Dement Geriatr Cogn Disord. 2001;12(3):232-6. PM: 11244218. [pmid: 11244218].
15 Wells GA, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. February 1, 2009. http://www.ohri.ca/programs/clinical_epidemiology/oxford.htm.
16 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews (Draft). Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf. May 27, 2009. 2007.
17 Barrett KE, Barman S, Boitano S, et al. Blood as a circulatory fluid and the dynamics of blood and lymph flow: introduction. Ganong's Review of Medical Physiology. New York. The McGraw-Hill Companies, Inc. 2009. 23:32.
18 Tretbar LL. Structure and function of the lymphatic system (Chapter 1). Lymphedema: Diagnosis and Treatment. London. Springer-Verlag London Limited. 1. 2008:1-11.
19 Morgan CL, Lee BB. Classification and Staging of Lymphedema (Chapter 3). Lymphedema: Diagnosis and Treatment. London. Springer-Verlag London Limited. 3. 2008:21-30.
20 Rockson SG, Rivera KK. Estimating the population burden of lymphedema. [Review] [109 refs]. Ann N Y Acad Sci. 2008;1131:147-54. [pmid: 18519968].
21 Centers for Disease Control and Prevention. Lymphatic Filariasis Fact Sheet. July 16, 2009. http://www.cdc.gov/ncidod/dpd/parasites/lymphaticfilariasis/factsht_lymphatic_filar.htm.
22 Norman SA, Localio AR, Potashnik SL, et al. Lymphedema in breast cancer survivors: incidence, degree, time course, treatment, and symptoms. J Clin Oncol. 2009;27(3):390-7. [pmid: 19064976].
23 Witte CL, Witte MH, Unger EC, et al. Advances in imaging of lymph flow disorders. [Review] [34 refs]. Radiographics. 2000;20(6):1697-719. [pmid: 11112825].
24 Dabrowski J, Merkert R, Kusmierek J. Optimized lymphoscintigraphy and diagnostics of lymphatic oedema of the lower extremities. Nucl Med Rev. 2008;11(1):26-9. [pmid: 19173185].
25 O'Mahony S, Rose SL, Chilvers AJ, et al. Finding an optimal method for imaging lymphatic vessels of the upper limb. Eur J Nucl Med Mol Imaging. 2004;31(4):555-63. [pmid: 14722673].
26 Balzarini A, Milella M, Civelli E, et al. Ultrasonography of arm edema after axillary dissection for breast cancer: a preliminary study. Lymphology. 2001;34:152-5. [pmid: 11783592].
27 Armer JM, Stewart BR. A comparison of four diagnostic criteria for lymphedema in a post-breast cancer population. Lymphat Res Biol. 2005;3(4):208-17. [pmid: 16379589].
28 Taylor R, Jayasinghe UW, Koelmeyer L, et al. Reliability and validity of arm volume measurements for assessment of lymphedema. Phys Ther. 2006;86(2):205-14. [pmid: 16445334].
29 Kato S, Shimoda H, Ji RC, et al. Lymphangiogenesis and expression of specific molecules as lymphatic endothelial cell markers. [Review] [124 refs]. Anatomical Science International. 2006;81(2):71-83. [pmid: 16800291].
30 Deltombe T, Jamart J, Recloux S, et al. Reliability and limits of agreement of circumferential, water displacement, and optoelectronic volumetry in the measurement of upper limb lymphedema. Lymphology. 2007;40(1):26-34. [pmid: 17539462].
31 Chen Y, Tsai H, Hung H, et al. Reliability study of measurements for lymphedema in breast cancer patients. Am J Phys Med Rehabil. 2008;87(1):33-8. Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=113&accno=2009858783;http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2009858783&site=ehost-live. [pmid: 17993983].
32 Gerber LH. A review of measures of lymphedema. [Review] [12 refs]. Cancer. 1998;83(12:Suppl American):2803-4. [pmid: 9874401].
33 Carati CJ, Anderson SN, Gannon BJ, et al. Treatment of postmastectomy lymphedema with low-level laser therapy: a double blind, placebo-controlled trial. [erratum appears in Cancer. 2003 Dec 15;98(12):2742]. Cancer. 2003;98(6):1114-22. [pmid: 12973834].
34 Nuutinen J, Ikaheimo R, Lahtinen T. Validation of a new dielectric device to assess changes of tissue water in skin and subcutaneous fat. Physiol Meas. 2004;25(2):447-54. ISI:000221075000006. [pmid: 15132310].
35 Cornish B. Bioimpedance analysis: scientific background. Lymphat Res Biol. 2006;4(1):47-50. [pmid: 16569208].
36 Armer JM, Radina ME, Porock D, et al. Predicting breast cancer-related lymphedema using self-reported symptoms. Nurs Res. 2003;52(6):370-9. [pmid: 14639083].
37 U.S Food and Drug Administration. Product Classification:System, Nuclear Magnetic Resonance Imaging. July 16, 2009. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPCD/classification.cfm?ID=4624.
38 U.S Food and Drug Administration. FDA 510k premarket notification: ultrasound. July 16, 2009. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPCD/classification.cfm?ID=4564.
39 U.S Food and Drug Administration. FDA 510K premarket notification: Analyzer Body Composition. July 16, 2009. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfpmn/pmn.cfm?ID=19276.
40 U.S Food and Drug Administration. FDA 510k premarket notification: monitor extracellular fluid, lymphedema, extremity. July 16, 2009. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMN/pmn.cfm?ID=27442.
41 Morgan CL. Medical Management of Lymphedema (Chapter 5). Lymphedema: Diagnosis and Treatment. London. Springer-Verlag London Limited. 5. 2008:43-53.
42 Cheville AL, McGarvey CL, Petrek JA, et al. Lymphedema management. [Review] [107 refs]. Semin Radiat Oncol. 2003;13(3):290-301. [pmid: 12903017].
43 Morris RJ. Intermittent pneumatic compression - systems and applications. [Review] [98 refs]. J Med Eng Technol. 2008;32(3):179-88. [pmid: 18432465].
44 International Society of Lymphology. The diagnosis and treatment of peripheral lymphedema. Consensus document of the International Society of Lymphology. [Review] [5 refs]. Lymphology. 2003;36(2):84-91. [pmid: 12926833].
45 Bernas M, Witte M, Kriederman B, et al. Massage therapy in the treatment of lymphedema. Rationale, results, and applications. [Review] [76 refs]. IEEE Eng Med Biol Mag. 2005;24(2):58-68. [pmid: 15825847].
46 Zuther J. Traditional massage therapy in the treatment and management of lymphedema. Massage Today. Jan. 2009;12(6):1. web only. 2009 Jan 1. http://www.massagetoday.com/mpacms/mt/article.php?id=10475.
47 Hayes SC, Reul-Hirche H, Turner J. Exercise and secondary lymphedema: safety, potential benefits, and research issues. Med Sci Sports Exerc. 2009;41(3):483-9. [pmid: 19204604].
48 Schmitz KH, Ahmed RL, Troxel A, et al. Weight lifting in women with breast-cancer-related lymphedema. [see comment]. New England Journal of Medicine. 2009;361(7):664-73. [pmid: 19675330].
49 Nouri K, Jimenez GP, Harrison-Balestra C, et al. 585-nm pulsed dye laser in the treatment of surgical scars starting on the suture removal day. Dermatol Surg. 2003;29(1):65-73. PM:12534515. [pmid: 12534515].
50 Balzarini A, Pirovano C, Diazzi G, et al. Ultrasound therapy of chronic arm lymphedema after surgical treatment of breast cancer. Lymphology. 1993;26(3):128-34. [pmid: 8258986].
51 Tidhar D, Drouin J, Shimony A. Aqua lymphatic therapy in managing lower extremity lymphedema. J Support Oncol. 2007;5(4):179-83. [pmid: 17500505].
52 The Lymphology Association of North America (LANA). website 2010. 2010. 1-4-2010. http://www.clt-lana.org/about/default.asp.
53 Jamison LJ. Aquatic therapy for the patient with lymphedema. Journal of Aquatic Physical Therapy. 2005;13(1):9-12.
54 Woods M. An audit of swollen limb measurements. Nursing Standard. 1994;9(5):24-6. [pmid: 7999565].
55 Carroll D, Rose K. Treatment leads to significant improvement. Effect of conservative treatment on pain in lymphoedema. Prof Nurse. 1992;8(1):32-3. [pmid: 1480641].
56 Karges JR, Mark BE, Stikeleather SJ, et al. Assessing the relationship between water displacement and circumferential measurements in determining upper extremity volume in women with lymphedema. Phys Ther. 1997;77:S109-S110.
57 Tsai HJ, Liu YX, Tsauo JY. Reliability study of lymphadema measurement. Formosan Journal of Physical Therapy. 2005;30:124-31.
58 Li X-J, Wang L. Radioisotope scanning evaluation on the improvement of postmastectomy upper extremity lymphedema in breast cancer patients following compression therapy. Journal of Clinical Rehabilitative Tissue Engineering Research. 2007;11(22):4329-32.
59 Oliel VS, Holt M. Lymfodembehandling - det fysioterapeutiske aspekt. Danske Fysioter. 1999;22:26-4.
60 Andersen JS. Lymfodem - nye behandlingsprincipper. Danske Fysioter. 2000;17:6-11.
61 Rudat CH. Die Lymphe - die reinigende Flussigkeit unseres Korpers. Natur und Heilen. 1999;76(9):548-52.
62 Kniazeva TA, Minenkov AA, Kul'chitskaia DB, et al. Effect of physiotherapy on the microcirculation in patients with lymphedema of lower extremities. Vopr Kurortol Fizioter Lech Fiz Kult. 2003;(1):30-2. [pmid: 12698704].
63 Ogawa Y, Hayashi K. 99mTc-DTPA-HSA lymphoscintigraphy in lymphedema of the lower extremities: diagnostic significance of dynamic study and muscular exercise. Kaku Igaku - Japanese Journal of Nuclear Medicine. 1999;36(1):31-6. [pmid: 10087763].
64 Watanabe K, Noikura T, Yamashita S, et al. Phase III trial of 99mTc-rhenium Colloid for lymphoscintigraphy. Kakuigaku. 1992;29(8):979-90.
65 O'Toole J, Russell T, Specht M, et al. Prospective evaluation of arm volume in breast cancer patients: determining a threshold for intervention. Rehabilitation Oncology. 2009;27(1):25-6. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010324841&site=ehost-live.
66 Mayrovitz NH, Sims N, Macdonald J. Assessment of limb volume by manual and automated methods in patients with limb edema or lymphedema. Adv Skin Wound Care. 2000;13(6):272-6. [pmid: 12669673].
67 Moseley A, Piller N. Reliability of bioimpedance spectroscopy and tonometry after breast conserving cancer treatment. Lymph Res Biol. 2008;6(2):85-7. [pmid: 18564923].
68 Hayes S, Janda M, Cornish B, et al. Lymphedema secondary to breast cancer: how choice of measure influences diagnosis, prevalence, and identifiable risk factors. Lymphology. 2008;41(1):18-28. [pmid: 18581955].
69 Spillane AJ, Saw RP, Tucker M, et al. Defining lower limb lymphedema after inguinal or ilio-inguinal dissection in patients with melanoma using classification and regression tree analysis. Ann Surg. 2008;248(2):286-93. [pmid: 18650640].
70 Godoy JM, Silva SH, Godoy MF. Sensitivity and specificity of combined perimetric and volumetric evaluations in the diagnosis of arm lymphedema. Prague Med Rep. 2007;108(3):243-7. [pmid: 18399061].
71 Ridner SH, Montgomery LD, Hepworth JT, et al. Comparison of upper limb volume measurement techniques and arm symptoms between healthy volunteers and individuals with known lymphedema. Lymphology. 2007;40(1):35-46. [pmid: 17539463].
72 Peer FI, Pui MH, Mosam A, et al. 99mTc-MIBI imaging of cutaneous AIDS-associated Kaposi's sarcoma. Int J Dermatol. 2007;46(2):166-71. [pmid: 17269969].
73 Damstra RJ, Glazenburg EJ, Hop WC. Validation of the inverse water volumetry method: A new gold standard for arm volume measurements. Breast Cancer Res Treat. 2006;99(3):267-73. [pmid: 16752072].
74 Hayes S, Cornish B, Newman B. Comparison of methods to diagnose lymphoedema among breast cancer survivors: 6-month follow-up. Breast Cancer Res Treat. 2005;89(3):221-6. [pmid: 15754119].
75 Mirnajafi A, Moseley A, Piller N. A new technique for measuring skin changes of patients with chronic postmastectomy lymphedema. Lymphat Res Biol. 2004;2(2):82-5. [pmid: 15615489].
76 Mellor RH, Bush NL, Stanton AW, et al. Dual-frequency ultrasound examination of skin and subcutis thickness in breast cancer-related lymphedema. Breast J. 2004;10(6):496-503. [pmid: 15569205].
77 Meijer RS, Rietman JS, Geertzen JH, et al. Validity and intra- and interobserver reliability of an indirect volume measurements in patients with upper extremity lymphedema. Lymphology. 2004;37(3):127-33. [pmid: 15560108].
78 Bland KL, Perczyk R, Du W, et al. Can a practicing surgeon detect early lymphedema reliably?. Am J Surg. 2003;186(5):509-13. [pmid: 14599616].
79 Karges JR, Mark BE, Stikeleather SJ, et al. Concurrent validity of upper-extremity volume estimates: comparison of calculated volume derived from girth measurements and water displacement volume. Physical Therapy. 2003;83(2):134-45. [pmid: 12564949].
80 Moseley A, Piller N, Carati C. Combined opto-electronic perometry and bioimpedance to measure objectively the effectiveness of a new treatment intervention for chronic secondary leg lymphedema. Lymphology. 2002;35(4):136-43. [pmid: 12570322].
81 Szuba A, Strauss W, Sirsikar SP, et al. Quantitative radionuclide lymphoscintigraphy predicts outcome of manual lymphatic therapy in breast cancer-related lymphedema of the upper extremity. Nucl Med Commun. 2002;23(12):1171-5. [pmid: 12464781].
82 Megens AM, Harris SR, Kim-Sing C, et al. Measurement of upper extremity volume in women after axillary dissection for breast cancer. Arch Phys Med Rehabil. 2001;82(12):1639-44. [pmid: 11733875].
83 Norman SA, Miller LT, Erikson HB, et al. Development and validation of a telephone questionnaire to characterize lymphedema in women treated for breast cancer. Phys Ther. 2001;81(6):1192-205. [pmid: 11380275].
84 Latchford S, Casley-Smith JR. Estimating limb volumes and alterations in peripheral edema from circumferences measured at different intervals. Lymphology. 1997;30(4):161-4. [pmid: 9476247].
85 Cornish BH, Bunce IH, Ward LC, et al. Bioelectrical impedance for monitoring the efficacy of lymphoedema treatment programmes. Breast Cancer Res Treat. 1996;38(2):169-76. [pmid: 8861835].
86 Roberts CC, Levick JR, Stanton AW, et al. Assessment of truncal edema following breast cancer treatment using modified Harpenden skinfold calipers. Lymphology. 1995;28(2):78-88. [pmid: 7564495].
87 Ward LC, Bunce IH, Cornish BH, et al. Multi-frequency bioelectrical impedance augments the diagnosis and management of lymphoedema in postmastectomy patients. Eur J Clin Invest. 1992;22(11):751-4. [pmid: 1478244].
88 Bates DO, Levick JR, Mortimer PS. Subcutaneous interstitial fluid pressure and arm volume in lymphoedema. International Journal of Microcirculation: Clinical & Experimental. 1992;11(4):359-73. [pmid: 1459796].
89 Tewari N, Gill PG, Bochner MA, et al. Comparison of volume displacement versus circumferential arm measurements for lymphoedema: Implications for the SNAC trial. ANZ J Surg. 2008;78(10):889-93. [pmid: 18959643].
90 Halaska MJ, Komarek V, Mala I, et al. A method for the detection of post-operative lymphoedema after operation for breast cancer: Multifrequency bioelectrical impedance analysis. J Appl Biomed. 2006;4(4):179-85.
91 Stanton AWB, Northfield JW, Holroyd B, et al. Validation of an opeoelectronic lomb volumeter (perometer). Lymphology. 1997;30(2):77-97. [pmid: 9215977].
92 Gebousky P, Karny M, Krizova H, et al. Staging of upper limb lymphedema from routine lymphoscintigraphic examinations. Comput Biol Med. 2009;39(1):1-7. [pmid: 19041964].
93 Mayrovitz HN, Davey S, Shapiro E. Local tissue water changes assessed by tissue dielectric constant: Single measurements versus averaging of multiple measurements. Lymphology. 2008;41(4):186-8. [pmid: 19306665].
94 Mayrovitz HN, Davey S, Shapiro E. Suitability of single tissue dielectric constant measurements to assess local tissue water in normal and lymphedematous skin. Clin Physiol Funct Imaging. 2009;29(2):123-7. [pmid: 19076729].
95 Cornish BH, Chapman C, Hirst C, et al. Early diagnosis of lymphoedema using multiple frequency bioimpedence. Lymphology. 2001;34(1):2-11. [pmid: 11307661].
96 Sagen A, Karesen R, Skaane P, et al. Validity for the simplified water displacement instrument to measure arm lymphedema as a result of breast cancer surgery. Archives of Physical Medicine & Rehabilitation. 2009;90(5):803-9. [pmid: 19406300].
97 Ridner SH, Dietrich MS, Deng J, et al. Bioelectrical impedance for detecting upper limb lymphedema in nonlaboratory settings. Lymphatic Research & Biology. 2009;7(1):11-5. [pmid: 19231915].
98 Ward LC, Czerniec S, Kilbreath SL. Operational equivalence of bioimpedance indices and perometry for the assessment of unilateral arm lymphedema. Lymphatic Research & Biology. 2009;7(2):81-5. [pmid: 19522677].
99 York SL, Ward LC, Czerniec S, et al. Single frequency versus bioimpedance spectroscopy for the assessment of lymphedema. Breast Cancer Research & Treatment. 2009;117(1):177-82. [pmid: 18563555].
100 Czerniec SA, Ward LC, Refshauge KM, et al. Assessment of breast cancer-related arm lymphedema--comparison of physical measurement methods and self-report. Cancer Invest. 2010;28(1):54-62. [pmid: 19916749].
101 Ward LC, Czerniec S, Kilbreath SL. Quantitative bioimpedance spectroscopy for the assessment of lymphoedema. Breast Cancer Research & Treatment. 2009;117(3):541-7. [pmid: 19082708].
102 Juni P, Altman DG, Egger M. Assessing the quality of randomised controlled trials. Egger M, Davey Smith G, Altman DG, editors. Systematic Reviews in Health Care: Meta-analysis in Context. London. BMJ Publishing Group. 5. 2001:87-108.
103 Radakovk N, Popovic-Petrovic S, Vranjes N, et al. A comparative pilot study of the treatment of arm lymphedema by manual drainage and sequential external pneumatic compression (SEPC) after mastectomy. Arch Oncol. 1998;6(4):177-8.
104 Kozanoglu E, Basaran S, Paydas S, et al. Efficacy of pneumatic compression and low-level laser therapy in the treatment of postmastectomy lymphoedema:a randomized controlled trial. Clin Rehabil. 2009;23(2):117-24. [pmid: 19164399].
105 Hou C, Wu X, Jin X. Autologous bone marrow stromal cells transplantation for the treatment of secondary arm lymphedema: a prospective controlled study in patients with breast cancer related lymphedema. Jpn J Clin Oncol. 2008;38(10):670-4. [pmid: 18776199].
106 Kessler T, de Bruin E, Brunner F, et al. Effect of manual lymph drainage after hindfoot operations. Physiother Res Int. 2003;8(2):101-10. [pmid: 12879732].
107 McKenzie DC, Kalda AL. Effect of upper extremity exercise on secondary lymphedema in breast cancer patients: a pilot study. J Clin Oncol. 2003;21(3):463-6. [pmid: 12560436].
108 Szuba A, Achalu R, Rockson SG. Decongestive lymphatic therapy for patients with breast carcinoma-associated lymphedema. A randomized, prospective study of a role for adjunctive intermittent pneumatic compression. Study # 1. Cancer. 2002;95(11):2260-7. [pmid: 12436430].
109 Johansson K, Lie E, Ekdahl C, et al. A randomized study comparing manual lymph drainage with sequential pneumatic compression for treatment of postoperative arm lymphedema. Lymphology. 1998;31(2):56-64. [pmid: 9664269].
110 Bertelli G, Venturini M, Forno G, et al. Conservative treatment of postmastectomy lymphedema: a controlled, randomized trial. Ann Oncol. 1991;2(8):575-8. [pmid: 1793725].
111 Szuba A, Achalu R, Rockson SG. Decongestive lymphatic therapy for patients with breast carcinoma-associated lymphedema. A randomized, prospective study of a role for adjunctive intermittent pneumatic compression. Study # 2. Cancer. 2002;95(11):2260-7. [pmid: 12436430].
112 Dini D, Del Mastro L, Gozza A, et al. The role of pneumatic compression in the treatment of postmastectomy lymphedema. A randomized phase III study. Ann Oncol. 1998;9(2):187-90. [pmid: 9553664].
113 Wilburn O, Wilburn P, Rockson SG. A pilot, prospective evaluation of a novel alternative for maintenance therapy of breast cancer-associated lymphedema [ISRCTN76522412]. BMC Cancer. 2006;6:84. [pmid: 16571129].
114 Williams AF, Vadgama A, Franks PJ, et al. A randomized controlled crossover study of manual lymphatic drainage therapy in women with breast cancer-related lymphoedema. Eur J Cancer Care. 2002;11(4):254-61. [pmid: 12492462].
115 Andersen L, Hojris I, Erlandsen M, et al. Treatment of breast-cancer-related lymphedema with or without manual lymphatic drainage--a randomized study. Acta Oncol. 2000;39(3):399-405. [pmid: 10987238].
116 Shaw C, Mortimer P, Judd PA. A randomized controlled trial of weight reduction as a treatment for breast cancer-related lymphedema. Cancer. 2007;110(8):1868-74. [pmid: 17823909].
117 Shaw C, Mortimer P, Judd PA. Randomized controlled trial comparing a low-fat diet with a weight-reduction diet in breast cancer-related lymphedema. Cancer. 2007;109(10):1949-56. [pmid: 17393377].
118 Kaviani A, Fateh M, Yousefi NR, et al. Low-level laser therapy in management of postmastectomy lymphedema. Lasers Med Sci. 2006;21(2):90-4. [pmid: 16673054].
119 Didem K, Ufuk YS, Serdar S, et al. The comparison of two different physiotherapy methods in treatment of lymphedema after breast surgery. Breast Cancer Res Treat. 2005;93(1):49-54. [pmid: 16184458].
120 Jahr S, Schoppe B, Reisshauer A. Effect of treatment with low-intensity and extremely low-frequency electrostatic fields (deep oscillation) on breast tissue and pain in patients with secondary breast lymphoedema. J Rehabil Med. 2008;40(8):645-50. [pmid: 19020698].
121 Maiya AG, Olivia ED, Dibya A. Effect of low energy laser therapy in the management of post-mastectomy lymphoedema. Physiotherapy Singapore. 2008;11(1):2-5.
122 Sitzia J, Sobrido L, Harlow W. Manual lymphatic drainage compared with simple lymphatic drainage in the treatment of post-mastectomy lymphoedema. Physiotherapy. 2002;88(2):99-107.
123 McNeely ML, Magee DJ, Lees AW, et al. The addition of manual lymph drainage to compression therapy for breast cancer related lymphedema: a randomized controlled trial. Breast Cancer Res Treat. 2004;86(2):95-106. [pmid: 15319562].
124 Damstra RJ, Partsch H. Compression therapy in breast cancer-related lymphedema: A randomized, controlled comparative study of relation between volume and interface pressure changes. J Vasc Surg. 2009;49(5):1256-63. [pmid: 19394553].
125 Pilch U, Wozniewski M, Szuba A. Influence of compression cycle time and number of sleeve chambers on upper extremity lymphedema volume reduction during intermittent pneumatic compression. Lymphology. 2009;42(1):26-35. [pmid: 19499765].
126 Bialoszewski D, Wozniak W, Zarek S. Clinical efficacy of kinesiology taping in reducing edema of the lower limbs in patients treated with the ilizarov method--preliminary report. Ortopedia Traumatologia Rehabilitacja. 2009;11(1):46-54. [pmid: 19240683].
127 Lau RW, Cheing GL. Managing postmastectomy lymphedema with low-level laser therapy. Photomedicine and Laser Surgery. 2009;27(5):763-9. [pmid: 19878027].
128 Tsai HJ, Hung HC, Yang JL, et al. Could Kinesio tape replace the bandage in decongestive lymphatic therapy for breast-cancer-related lymphedema? A pilot study. Support Care Cancer. 2009;17(11):1353-60. [pmid: 19199105].
129 Irdesel J, Kahraman CS. Effectiveness of exercise and compression garments in the treatment of breast cancer related lymphedema. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi. 2007;53(1):16-21.
130 Berlin E, Gjores JE, Ivarsson C, et al. Postmastectomy lymphoedema. Treatment and a five-year follow-up study. Int Angiol. 1999;18(4):294-8. [pmid: 10811517].
131 Pinell XA, Kirkpatrick SH, Hawkins K, et al. Manipulative therapy of secondary lymphedema in the presence of locoregional tumors. Cancer. 2008;112(4):950-4. [pmid: 18085587].
132 Brambilla L, Tourlaki A, Ferrucci S, et al. Treatment of classic Kaposi's sarcoma-associated lymphedema with elastic stockings. J Dermatol. 2006;33(7):451-6. [pmid: 16848816].
133 Johansson K, Albertsson M, Ingvar C, et al. Effects of compression bandaging with or without manual lymph drainage treatment in patients with postoperative arm lymphedema. Lymphology. 1999;32(3):103-10. [pmid: 10494522].
134 Frischenschlager O, Fialka V, Schindt L. Comparison of two rehabilitation programmes for lymphedema following ablatio mammae: emotional well-being. Eur J Phys Med Rehabil. 1991;1(5):123-5.
135 Tretbar LL, Morgan CL, Lee BB, et al. Lymphedema: Diagnosis and Treatment. London. Springer-Verlag London Limited. 2008.
136 Mayrovitz HN. Assessing lymphedema by tissue indentation force and local tissue water. Lymphology. 2009;42(2):88-98. [pmid: 19725274].
137 Sitzia J. Volume measurement in lymphoedema treatment: examination of formulae. European Journal of Cancer Care. 1995;4(1):11-6. [pmid: 7620649].
138 Schmitz KH, Troxel AB, Cheville A, et al. Physical activity and lymphedema (the PAL trial): Assessing the safety of progressive strength training in breast cancer survivors. Contemporary Clinical Trials. 2009;30(3):233-45. [pmid: 19171204].
139 Halaska M, Strnad P, Chod J, et al. Detection of postoperative lymphoedema in patients with breast cancer. [Czech]. Ceska Gynekol. 2007;72(4):299-304. [pmid: 17966613].
140 Schuchhardt C. Volume measurement of extremities comparing optoelectronic and plethysmographic methods. [German]. Lymphologie in Forschung und Praxis. 2003;7(1):22-4.
141 Campisi C, Boccardo F, Zilli A, et al. Lymphedema secondary to breast cancer treatment: possibility of diagnostic and therapeutic prevention. [Italian]. Ann Ital Chir. 2002;73(5):493-8. [pmid: 12704989].
142 Hansdorfer-Korzon R, Bakula S, Nowakowski M. The role of B-MODE ultrasound examination compared to limb circumference measurement in the diagnosis of early stages of lymphatic edema in women after mastectomy. [Polish]. Fizjoterapia Polska. 2005;5(1):31-40.
143 Acebes O, Renau E, Sansegundo R, et al. Valoracion del linfedema postmastectomia. Estudio comparativo de dos metodos de medicion. Rehabilitacion. 1999;33(3):190-4.
144 Herpertz U. Outcome of various inpatient lymph drainage procedures. [German]. Zeitschrift fur Lymphologie - Journal of Lymphology. 1996;20(1):27-30. [pmid: 8768046].
145 Hanasz-Sokolowska D, Kazmierczak U, Hagner W, et al. The effectiveness of conservative methods of rehabilitation (PT) in treatment of lymphoedema after mastectomy operation. [Polish]. Fizjoterapia Polska. 2006;6(1):67-71.
146 Gerasimenko VN, Grushina TI, Lev SG. A complex of conservative rehabilitation measures in postmastectomy edema. [Russian]. Vopr Onkol. 1990;36(12):1479-85. [pmid: 2288127].
147 Ferrandez J. Assessment of two compressive bandages for secondary lymphedema of the upper limb: a prospective multicentric study. [French]. Kinesitherapie Revue. 2007;(67):30-5. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2009646641&site=ehost-live;Publisher URL: www.cinahl.com/cgibin/refsvc?jid=3259&accno=2009646641.
148 Lee ES, Kim SH, Kim SM, et al. Effects of educational program of manual lymph massage on the arm functioning and the quality of life in breast cancer patients. [Korean]. Daehan Ganho Haghoeji. 2005;35(7):1390-400. [pmid: 16418566].
149 Dittmar A, Krause D. A comparison of intermittent compression with single and multi-chamber systems in treatment of secondary arm lymphedema following mastectomy. [German]. Zeitschrift fur Lymphologie - Journal of Lymphology. 1990;14(1):27-31. [pmid: 2238801].
150 Husarovicova E, Husarovicova V. The rehabilitation influence to reduction of lymphoedema. [Slovak]. Rehabilitacia. 2006;43(1):53-7.
151 Petruseviciene D, Krisciunas A, Sameniene J. Efficiency of rehabilitation methods in the treatment of arm lymphedema after breast cancer surgery. [Lithuanian]. Medicina (Kaunas). 2002;38(10):1003-8. [pmid: 12532709].
152 Murphy JM, Berwick DM, Weinstein MC, et al. Performance of screening and diagnostic tests. Application of receiver operating characteristic analysis. Arch Gen Psychiatry. 1987;44(6):550-5. PM:3579501. [pmid: 3579501].
153 Schulz KF, Altman DG, Moher D, et al. CONSORT 2010 Statement: updated guidelines for reporting parallel group randomised trials. BMJ. 2010;340:c332. [doi: 10.1136/bmj.c332]. http://www.bmj.com. [pmid: 20332509].