# Executive Summary

## Introduction

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this technology assessment from the Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the McMaster University Evidence-based Practice Center (MU-EPC) (Contract Number: HHSA 290-2007-10060I). The primary goals of the assessment were to examine the performance of diagnostic tests for preclinical or clinically significant secondary lymphedema, as well as to assess conservative, nonpharmacological, and nonsurgical treatments for secondary lymphedema.

## Narrative Review

Lymphedema is a pathological condition of the lymphatic system that results from an accumulation of protein rich fluid in the interstitial space because of congenital or acquired damage to the lymphatic system. Clinically, it presents as edema.1

Primary lymphedema occurs in patients who have a congenital abnormality or dysfunction of their lymphatic system.2,3 Secondary lymphedema is an acquired condition resulting from the disruption or obstruction of the normal lymphatic system. Secondary lymphedema can be caused by disease, trauma, or an iatrogenic process such as surgery or radiation.2

Lymphedema is usually staged by observing a patient’s physical condition (Table 1).4 Historically there have been 3 stages of classification but recently Stage 0 (subclinical lymphedema) is increasingly recognized as a stage of lymphedema.

Table 1 Stages of Lymphedema

Stage | Description
Stage 0 | A latent or subclinical condition where swelling is not evident despite impaired lymph transport. Stage 0 may exist months or years before overt edema occurs (Stage I-III).
Stage I | Early accumulation of fluid relatively high in protein content (e.g., in comparison with ‘venous’ edema) that subsides with limb elevation. Pitting may occur. An increase in proliferating cells may be seen.
Stage II | Limb elevation alone rarely reduces tissue swelling and pitting may or may not occur as tissue fibrosis develops.
Stage III | Lymphostatic elephantiasis. Pitting is absent and trophic skin changes such as acanthosis, fat deposits, and warty overgrowths develop.

In the United States, the most common cause of secondary lymphedema is malignancies and their related treatment (i.e., surgery, radiation).

A sentinel lymph node is any lymph node that receives direct drainage from a tumor site. Sentinel lymph nodes can be biopsied and examined for the presence of micrometastases.5 Sentinel lymph node biopsy (SLNB) is now part of the standard of care for patients with breast cancer and melanoma. SLNB has been shown to decrease the incidence of lymphedema, although the amount of the reduction is still being studied. A 5 year, prospective trial followed 936 women with breast cancer who underwent SLNB alone or SLNB in combination with axillary lymph node dissection (ALND). The incidence of lymphedema was 5 percent in the SLNB group and 16 percent in the SLNB/ALND group.6 The Royal Australian College of Surgeons conducted an international, multicenter, randomized controlled trial (RCT) that examined SLNB versus axillary dissection in women with breast cancer. The study found that women receiving SLNB had less lymphedema, less pain, and less arm dysfunction.7

Lymphedema is typically diagnosed by clinical history and physical examination.2 When imaging tests are required to assist in diagnosis, lymphoscintigraphy is often the test of first choice.3 When lymphoscintigraphy is not available, magnetic resonance imaging (MRI) and computed tomography (CT) can also be used.3

The U.S. Food and Drug Administration (FDA) regulates the marketing and use of medical devices in the United States. The FDA does not specifically mention the use of lymphoscintigraphy, MRI, ultrasound, or CT to diagnose lymphedema.

There are several nonpharmacological and nonsurgical treatments for lymphedema, including: compression techniques (e.g., multilayer bandaging techniques, self adherent wraps, compression garments at prescribed pressure gradients); intermittent pneumatic compression (IPC); decongestive therapy (also known as complex or complete decongestive therapy or complex decongestive therapy [CDT]); manual lymphatic drainage; exercise; laser treatment; ultrasound, and aquatherapy. No single treatment is considered usual care for lymphedema. Treatments are typically administered by physical or occupational therapists, though massage therapists, nurses, and physicians may also perform certain kinds of lymphedema treatment.

## Methods

### Literature Review

The following electronic databases were searched by exploding the subject heading ‘lymphedema’ and searching it as a textword (lymphedema or lymphoedema). Terms for complete decongestive therapy, manual lymphatic drainage, and intermittent pneumatic compression were included in the search. There were no language limitations for this search.

1. MEDLINE^®^ (1990 – January 19, 2010);
2. EMBASE^®^ (1990 – January 19, 2010);
3. Cochrane Central Register of Controlled Trials^®^ (1990 – January 19, 2010);
4. AMED (1990 – January 19, 2010); and
5. CINAHL (1990 – January 19, 2010).

Further searches were conducted of reference lists of recently published review articles2,8-11 and bibliographies of extracted articles.

Inclusion/exclusion criteria. For the diagnostic section, we included articles published in the English language that examined the sensitivity and specificity, or psychometric properties (e.g., reliability, validity, responsiveness) of diagnostic tests for lymphedema. Included articles had to contain an evaluation of the diagnostic test(s) on subjects with secondary lymphedema. For the treatment section, we included articles published in the English language, provided they were RCTs or observational studies with comparison groups (e.g., cohort, case control). We included studies of pediatric and adult patients who received any treatment for secondary lymphedema (except drug therapy or surgery) following any form of illness with the exception of filariasis infection.

### Study Selection and Extraction

A team of trained raters independently applied the inclusion and exclusion criteria to three levels of screening: I – title and abstract first review; II – title and abstract second review; III – full text. Articles that passed full text screening proceeded to full data extraction.

Two raters independently assessed the quality of the extracted articles. The quality of diagnostic studies was assessed using the Quality Assessment of Diagnostic Accuracy Studies scale (QUADAS).12 The quality of treatment studies was assessed using two scales, the modified Jadad scale13,14 for RCTs and the Newcastle-Ottawa Scale (NOS)15 for cohort and case control studies. The overall quality of the extracted articles was rated ‘good’, ‘fair’, or ‘poor’ in accordance with the AHRQ’s methods guide.16

### Non-English Language Studies

In response to peer review of the draft report, we reran the literature search a second time to identify non-English language articles, which were screened at three levels as described above. The purpose was to examine whether the non-English language literature was substantively different from the English language literature. We did not extract data from the non-English language articles that survived the screening process. Rather, we provided a written summary of the main contents of these articles and discussed whether (and how) they differed from the English language literature.

## Results

### Diagnosis

Question 1. What is the performance of diagnostic tests for preclinical and/or clinically significant lymphedema?

a) What inclusion criteria (including patient demographics, signs, and symptoms) were used in studies evaluating the performance of diagnostic tests of lymphedema?

Most of the diagnosis studies involved persons with breast cancer. The generally middle-aged nature of study subjects reflected the fact that most studies involved cancer patients, who are typically diagnosed and treated in middle age or later. Other disease related inclusion criteria were melanoma tumor removal, AIDS and Kaposi’s Sarcoma, or lymphedema diagnosis. For comparative purposes, many diagnostic studies also included nondiseased persons, such as clinic staff, healthy patients, or medical students, and surgical residents.

b) Is there any “gold standard” method to formally grade or measure the severity of lymphedema?

Based on the evidence in the extracted studies, there does not appear to be a gold standard to formally grade or measure the severity of lymphedema.

c) What comparators were used in the studies of diagnostic tests? Was the test compared to a “gold standard”, bedside exam, radiologic investigation, or other means?

Although rarely identified as gold standards, the frequency of use of different measures of limb volume or circumference would suggest that these measures are the de facto gold standards for diagnosing secondary lymphedema.

d) What is the sensitivity and specificity of tests used to diagnose lymphedema?

In the eight studies that contained examinations of the sensitivity and specificity of diagnostic tests for secondary lymphedema, sensitivities ranged from 5 to 100 percent (most were at least 40 or 50 percent or above) and specificities ranged from 71 to 100 percent.

e) What are the psychometric properties (reliability, validity, responsiveness) of these diagnostic methods?

Reliability. There is consistent evidence to indicate that lymphedema can be reliably measured using circumferential measures or volume displacement (although volume displacement calculated using Sitzia’s method tended to produce the lowest intraclass correlation coefficients, which are measures of reliability). There is too little evidence to draw conclusions about the reliability of other tests such as tonometry, ultrasound, lymphoscintigraphy, or bioimpedance.

Validity. Based on consistently high correlation coefficients, there is strong evidence that limb volume and circumference are interchangeable among one another.

Responsiveness. Only two of the studies included in this report evaluated the responsiveness to change of diagnostic tests for secondary lymphedema. The dearth of evidence on this topic prohibits one from drawing firm conclusions about responsiveness.

f) How frequently and for how long should patients be measured for the development of lymphedema or its subclinical precursor? Does this vary with the diagnostic test method?

There is no evidence to answer these key questions as none of the included diagnostic studies were intended to address either question.

g) Does the diagnostic test method influence the choice of lymphedema treatment or patient outcome? What outcomes were measured in studies of diagnostic tests of lymphedema?

There is no evidence in the 41 diagnostic testing studies to answer either of these questions.

### Treatment

Question 2. What were the patient selection criteria in the studies (inclusion and exclusion criteria)? Did they differ by treatment modality?

The major selection criterion in most of the 36 treatment studies was that persons had to have lymphedema secondary to breast cancer. Some studies contained specification that participants had to be in remission, have no relapse, or have no metastases. Various studies defined lymphedema as ‘mild’, ‘chronic’, or ‘moderate to severe’; other definitions included categorization of lymphedema by excess volume in the affected limb, degree of swelling and excess volume, or degree of swelling alone. There was no evidence to suggest that patient selection criteria differed by treatment modality.

Question 3. What were the criteria used to initiate treatment for lymphedema? When was treatment initiated compared to the time of onset of the lymphedema? What were the criteria used to stop therapy? Did these criteria vary with treatment modality?

In all 36 treatment studies extracted for this report, diagnosis of lymphedema was the only specific criteria used to initiate treatment. Therefore, no evidence exists to provide a clear answer to this key question.

Only five studies reported specific criteria to stop treatment. This number is too small to assess whether stopping criteria varied with treatment modality.

Question 4. Who provided the treatments in the studies? What information was provided on their professional training or certification in lymphedema care?

The authors of 17 of the 36 treatment studies did not detail who provided the lymphedema treatment. In the other 19 studies, the primary providers were physiotherapists.

Question 5a. Was one type of pneumatic compression device and sleeve (e.g., nonsegmented compression device, sequential segmented compression, or segmented compression with calibrated gradient pressure) more effective in reducing lymphedema than another for any type of lymphedema along the continuum, or patient characteristic (e.g., demographics, comorbidities)?

There was a lack of evidence from which to determine whether one type of intermittent pneumatic compression (IPC) device and sleeve were more effective than others across the continuum.

None of the extracted studies broke down treatment results by patient characteristics. Therefore, no evidence exists to assess whether one type of IPC device and sleeve were more effective in reducing lymphedema based on specific sets of patient characteristics.

Question 5b. Did the studies of an IPC for lymphedema in patients with comorbidities such as wounds, arterial and/or venous insufficiency, diabetes, congestive heart failure, infection, etc., report the need to modify their treatment protocols? Did it affect treatment outcome?

There were no reports in the extracted studies of the need to modify treatment protocols on account of comorbidity.

Question 5c. Did the timing of IPC application and/or the sequence of use of the various IPC device types (either alone or in combination with other therapies) influence outcomes either positively or negatively?

Evidence to address whether the timing of the IPC application might have influenced the study outcomes was inconclusive. For sequence of use, the evidence was inconclusive as well.

Question 6. What protocols for single modality treatments resulted in the best outcomes of lymphedema therapy? Consider parameters such as usage schedules and characteristics of treatment such as intensity, duration, frequency and setting (self administered at home versus professionally administered applied in a medical clinic), and, if applicable, pumping times/cycles and pressures.

There were too few studies, and too much methodological heterogeneity, to allow for an ascertainment of whether certain treatment protocols would lead to better outcomes.

Question 7: Were there any treatments, combinations of treatment methods, or sequence of treatments shown to be more effective or ineffective for any type of lymphedema along the continuum, or patient characteristics (e.g., demographics or comorbidities)? Of particular interest: Is there evidence that the use of compression sleeves or low stretch bandaging is effective in maintaining reductions in lymphedema achieved through the use of other modalities (e.g., IPC, manual lymphatic drainage, exercise)?

There is no evidence to answer either part of this question. In no group of studies were the populations defined or the results reported in such a degree of detail that it was possible to identify groups of patients for whom these treatments are more, or less, effective. No studies were designed to examine the role of sleeve or bandaging in maintaining the benefits of initial treatment.

Question 8: What comparators were used in the studies? Are these comparators consistent with usual care for lymphedema?

Many treatments have been suggested to provide benefit for patients with lymphedema. Despite this, no single treatment has emerged as a gold standard in clinical trials. Due to this, there appears to be no agreement on a standard comparator for RCTs.

Question 9: What outcomes were measured in studies of lymphedema therapy? How effective were these treatment methods in reducing lymphedema?

Multiple outcomes were used in these reports (e.g., changes in limb volume or circumference, subjective symptoms [e.g., pain], range of joint motion, intra and extra cellular fluid levels through bioimpedance). Objective measurements, usually relating to some sort of assessment of limb volume, were the most frequently reported outcomes.

Question 10: Did any studies show that the time of treatment initiation (single modality or combination therapy) relative to symptom onset, any other lymphedema characteristics, or any patient characteristics influenced or predicted treatment outcome?

As few studies were sufficiently powered to detect a difference in the primary outcome (often defined as a reduction in lymphedema swelling over time), most trials were limited in their ability to detect differences in patient subgroups which were predictive for response. Few trials randomized patients with a stratification scheme or performed adjusted analyses to allow for detection of predictive factors.

Question 11: What was the length of followup in studies of lymphedema therapy? How long were the benefits of treatment maintained?

Considering the chronicity of lymphedema, very few trials performed long term followup in their study populations. Treatment benefits were shown to persist for up to 12 weeks in some studies with short term followup periods. Only eight of 36 studies reported outcomes at 6 months or more, with benefits shown to last for up to one year in some cases, provided there was use of maintenance therapy (i.e., elastic sleeve).

Question 12: What harms have been reported associated with the various treatments for lymphedema? Do any patient characteristics (e.g., demographics, comorbidities) or etiology of lymphedema increase the risk of these harms?

The majority of withdrawals and adverse events were related to treatment scheduling or disease recurrence, neither of which would be the direct result of therapy. Adverse events likely related to study therapy were all rare and were not shown to have a major clinical impact in any of the reviewed studies. No studies reported on factors which may increase the risk of harms associated with treatment.

### Non English Language Studies

Five diagnosis and 8 treatment articles in languages other than English passed through the screening process. These articles did not contain any substantive information that would alter our responses to the key questions.

## Discussion

Most of the diagnostic accuracy and treatment studies were conducted in persons with a history of breast cancer. The heterogeneity of the evidence in these studies was too substantial to enable one to draw conclusions about the type of diagnostic test that would be most appropriate for diagnosing secondary lymphedema. The heterogeneity was also substantial enough to prevent one from ascertaining the optimal therapy (or set of therapies) for treating secondary lymphedema.

Based on the evidence, limb and volume circumference are the de facto ‘gold standard’ tests to diagnose secondary lymphedema. However, the evidence does not suggest a standard threshold or cut off point to indicate the presence or absence of lymphedema. Similarly, there is no consistent means of actually measuring volume or circumference. Although validity assessment suggests good interchangeability between different measures of limb volume or circumference, there was no evidence to suggest an adequate diagnostic testing protocol. The evidence from the studies failed to provide an indication of the most suitable frequency of testing or the time spans within which testing should be done. Additionally, there was no evidence to suggest whether the type of diagnostic test would have an affect on the choice of treatment or on patient outcomes.

Regarding treatment for secondary lymphedema, there was no evidence concerning the optimal criteria to initiate or stop treatment. While the studies suggested that most treatments did reduce the size of the lymphatic limb, there was too much heterogeneity in terms of treatments, inclusion and exclusion criteria, and treatment protocols to suggest the optimality of one type of treatment over another. Despite the multiplicity of inclusion and exclusion criteria, almost all of the extracted studies did not contain reports of treatment benefits in any subgroup of patients.

The methodological quality of the extracted diagnosis and treatment studies was generally ‘fair’. The authors of some studies omitted the reporting of fundamental elements of their research. There were reliability articles that did not contain mention of the intervals between administrations of the tests of interest, the validity studies omitted an indication of whether index test results were interpreted without knowledge of reference test results, and the majority of RCTs did not include comments on whether outcome assessors were blinded. Quality did not appear to play a major role in the interpretation of the answers to the key questions.

## Conclusion

Although a great deal of research into the diagnosis and treatment of secondary lymphedema has already been undertaken, there is no evidence to suggest an optimal diagnostic testing protocol, an optimal frequency or duration of treatment, the most efficacious treatment combinations (including the use of maintenance therapy), the length of time for which persons should be tested or treated for lymphedema, and whether certain tests or treatments may benefit some types of patients more than others. The field of research into secondary lymphedema is ripe for advancement and the contents of this report may serve as a springboard to guide future scientific endeavors in this domain.