# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Reviewer Name: Jane M. Armer, PhD, RN, FAAN
  Position & Affiliation: Professor, Sinclair School of Nursing, Director, Nursing Research, Ellis Fischel Cancer Center, Director, American Lymphedema Framework Project
  City, State: Columbia, MO
- Reviewer Name: Lyn Kligman, RN, MN
  Position & Affiliation: Advanced Practice Nurse at the London. Regional Cancer Program, London Health Sciences Centre
  City, Province: London, ON (Canada)
- Reviewer Name: Lucinda (Cindy) Pfalzer, PT, MA, PhD
  Position & Affiliation: Physical Therapy Dept, University of Michigan-Flint, Flint, Michigan, Professor of Physical Therapy and Associate Director for Research and Post Professional Education
  City, State: Flint, MI